# Acknowledgments

This study was developed by the RTI-UNC Evidence-based Practice Center under contract to the Agency for Healthcare Research and Quality (Contract No. 290-97-0011), Rockville, MD. We acknowledge the assistance of Jacqueline Besteman, JD, MA, EPC Program Officer; David Atkins, MD, MPH, Chief Medical Officer, Center for Practice and Technology Assessment, AHRQ; and Dana Best, MD, MPH, the AHRQ Task Order Officer. We extend our appreciation as well to RTI-UNC EPC staff, including Russell Harris, MD, MPH, co-director of the EPC's Clinical Prevention Center; Sonya Sutton, BSPH, Sheila White, and Loraine Monroe of Research Triangle Institute; and Mark Dowell and Carol Krasnov of the University of North Carolina at Chapel Hill Cecil R. Sheps Center for Health Services Research. Finally, we thank the external peer reviewers of the draft of this review: Robert Smith, MD, American Cancer Society, Atlanta, GA; Jerome B. Simon, MD, Hotel Dieu Hospital, Kingston, Ontario, Canada; Sidney Winawer, MD, Memorial Sloan-Kettering Cancer Center, New York, NY; Ann G. Zauber, Ph.D., Memorial Sloan-Kettering Cancer Center, New York, NY; Mary F. Mitchell, American College of Obstetricians and Gynecologists, Washington, DC; Ralph J. Anderson, MD, American College of Obstetricians and Gynecologists, Washington, DC; Vincenza Snow, MD, American College of Physicians/American Society of Internal Medicine, Boston, MA; Robert Fletcher, MD, Harvard Pilgrim Health Care, Boston, MA; Joe Selby, MD, MPH, Kaiser Permanente, Oakland, CA; and Robin McLeod, MD, Canadian Task Force on Preventive Care, Toronto, Ontario, Canada.