# Discussion

## Overall Findings of Effectiveness and Cost-Effectiveness

Our systematic review supports the effectiveness of screening as a means of reducing colorectal cancer mortality. Table 6 summarizes the strength of evidence supporting each of the different means of screening for colorectal cancer. For FOBT, 3 high-quality randomized trials have shown disease-specific mortality reductions of 15% to 33% over 8 to 13 years. High-quality case-control studies have shown that sigmoidoscopy and possibly colonoscopy are associated with decreased mortality within the reach of the scope. The combined strategy of FOBT and sigmoidoscopy is supported by 1 nonrandomized trial showing reduction in mortality with the addition of FOBT to rigid sigmoidoscopy ^ 47 ^ and by indirect evidence showing increased yield with both tests compared with FOBT alone.

Table 6. Strength of Evidence about Screening Strategies

Test | Direct?* Evidence | Evidence Level | Internal Validity | External Validity
Fecal occult blood testing | Y | I | G | G
Sigmoidoscopy | Y | II | G | F
Fecal occult blood testing and sigmoidoscopy combined | +/- | II | F | F
Double contrast barium enema | N | III | F | F
Colonoscopy | +/- | II | F | F
* +/- indicates not sure

Although barium enema or virtual colonoscopy have not been studied as extensively as other modalities for screening, some indirect evidence suggests that they may also be effective but further data are required in screening populations. Multiple cost-effectiveness analyses have combined these indirect data and estimated that screening by any of the commonly considered strategies appears to prevent morbidity and mortality with cost-effectiveness ratios that compare favorably with other acceptable preventive strategies, such as mammography in women over age 50.

Although colorectal cancer screening is supported by strong direct and indirect evidence, current data are insufficient to define which strategy is most effective or cost-effective. In the face of good general evidence supporting screening but uncertainty about the most effective method for doing so, providers and patients may benefit from discussing the pros and cons of the different methods and incorporating patients' preferences in the decision about how to screen. Future developments with respect to new screening modalities, better chemoprophylactic agents, and improved understanding of the effects of diet and exercise on disease incidence may change the available options for reducing disease burden in average-risk patients.

## Future Research Needs

Several areas of colorectal cancer screening and prevention warrant additional research. First, there is a critical need to learn more about adherence to screening among informed patients. Second, we need better data on the real-world complication rates of colonoscopic screening and polypectomy, including whether complications become more or less likely as volume increases. The accuracy of barium enema, virtual colonoscopy, and genetic stool tests (or other novel noninvasive tests) should be evaluated in screening populations. Some have called for a randomized trial of colonoscopy to determine its actual effectiveness. The cost of such a trial, particularly if colonoscopy were to be compared to other screening modalities rather than to no screening, would be quite high; and many years of follow-up would be required for differences to emerge. Additional data from randomized trials are also needed to help improve understanding of the effectiveness of chemopreventive agents such as nonsteroidal anti-inflammatory drugs, calcium, or estrogen. Behavioral factors, including physical activity, dietary fat, dietary fiber, and fruit and vegetable consumption, appear to be related to colorectal cancer incidence; further research is needed to determine better if these relationships are causal or are the result of uncontrolled confounding.

Despite its apparent effectiveness, colorectal cancer screening is currently underutilized by age-eligible adults. The multiple reasons for low utilization include patient-, provider-, and system-specific barriers.^ 32 ^ Effective colon cancer screening requires an ongoing effort. Screening with FOBT, for example, requires offering testing to 1,000 people for 10 years to same 1 life. Although this level of effort may seem inefficient or low yield, the potential benefit is large and the costs per person are small, thus, the cost-effectiveness ratio is very favorable compared with other preventive measures. Several strategies have shown effectiveness in raising screening rates, at least in some settings over the short term. These include reminder systems, patient decision aids, and mass screening efforts through employers or other organizations. Further research is needed to determine whether such systems can maintain their effect over time.