# Methods

We document here the procedures that the Research Triangle Institute - University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop this systematic review on screening for colorectal cancer.^ 17 ^ We describe development of the analytic framework and key questions, management of the literature search and synthesis, and conduct of the external peer review process. During these steps, EPC staff collaborated with two members of the USPSTF who acted as liaisons for this topic; they are co-authors of this review. The interactions took place chiefly by electronic mail and telephone conference calls. Steps in the development of this review were presented at USPSTF meetings in December 2000 and March 2001, when EPC staff and USPSTF members were able to discuss the analytic framework, key questions, and final draft findings and conclusions.

## Analytic Framework and Key Questions

The USPSTF examined the following overarching key question related to colorectal cancer screening: What are the benefits and adverse effects of screening average-risk adults over the age of 50 for colorectal cancer with office FOBT (oFOBT) and DRE, home FOBT, sigmoidoscopy, FOBT and sigmoidoscopy together, double contrast barium enema (DCBE), colonoscopy, or computed tomography (CT) colography? Each major testing strategy was examined separately, yielding seven subsidiary key questions.

To guide the review process, the authors developed the analytic framework depicted in Figure 2. The framework begins with asymptomatic adults ages 50 and older with no special risk factors for colorectal cancer. Screening of high-risk patients is addressed separately. Average-risk adults can undergo one of several strategies for screening. The screening strategies involve 1 or more tests that are repeated at some interval. Harms, including complications of the screening test, false positives, and economic costs, can arise at the screening phase. Persons screening negative are retested after some interval of time.

Figure 2. Colorectal Cancer (CRC) Screening: Analytic Framework

Persons screening positive by any method other than screening colonoscopy then undergo diagnostic colonoscopy. If the colonoscopy is negative for adenomas and cancers, screening can be suspended for at least 5 years. If the colonoscopy identifies neoplasms, they are biopsied. Adenomatous polyps usually can be removed during the initial colonoscopy. If cancer is detected, the patient receives further diagnostic studies to assess the stage of disease and then receives treatment (usually surgery, with radiotherapy or chemotherapy as adjuvant therapy in some circumstances). Harms can again arise at the time of colonoscopy or from treatment. Detection and removal of adenomas can prevent future cancers. Early detection and treatment of early-stage cancers can reduce colorectal cancer mortality.

## Literature Searching and Analysis

We used the second edition of the Guide to Clinical Preventive Services, existing systematic reviews, focused MEDLINE literature searches from 1966 through September 2000, review of the British National Health Service Economic Evaluation database, and hand-searches of key articles to identify the literature relevant to our key question. For those questions for which we performed MEDLINE searches, 1 reviewer examined the abstracts of the articles identified in the initial search to determine relevancy. A second reviewer examined the excluded articles and differences were resolved by consensus. Two reviewers examined the full text of the remaining articles to determine final eligibility.

We then abstracted the final set of eligible articles and created evidence tables. When systematic reviews were considered for inclusion, two investigators examined each review to assure that it followed methods similar to those used in our searches.

## Peer Review Process

A draft version of this report underwent review by several content experts and stakeholders (see acknowledgements). Based on their comments and those of the USPSTF members, the report was revised.