# Introduction

## Burden of Suffering and Epidemiology

Colorectal cancer is the fourth most common form of cancer in the United States and has the second highest mortality rate, accounting for about 130,000 new cases and about 56,000 deaths in the year 2000.^ 1 ^ The incidence of colorectal cancer is low until ages 45 to 50 years; it then rises throughout the remainder of a person's lifetime. Mortality from colorectal cancer begins to rise about 10 years after incidence rises. Men are slightly more likely to develop colorectal cancer than women, but the risk is high enough for both men and women potentially to benefit from screening; African-Americans are more likely to die from colorectal cancer than caucasians. Figure 1 shows the incidence and mortality of colorectal cancer by age and gender.^ 2 ^

Figure 1. Cancers of the Colon and Rectum: Average Annual Age-Specific SEER Incidence per 100,000 Persons and U.S. Mortality Rates By Gender, 1992-1996

A 50-year-old person has about a 5% lifetime risk of being diagnosed with colorectal cancer and a 2.5% chance of dying from it.^ 3 ^ Currently, 35% to 40% of patients diagnosed with colorectal cancer are detected when the cancer is localized; 35% to 40% have regional spread; and 20% to 25% have distant metastases.^ 2 ^ Estimated 5-year survival is greater than 90% in persons with Dukes' Stage A cancers, 80% for Dukes' Stage B, 65% in persons with regional spread (Dukes' C), and 8% in those with Stage D cancers (distant metastases). The average patient dying of colorectal cancer loses 13 years of life.^ 1 ^

### Polyps and Cancer

There are two types of polyps: hyperplastic and adenomatous. Hyperplastic polyps do not become cancers and require no further attention here. Some adenomatous polyps develop into cancer but most will not. The prevalence of adenomatous polyps at age 50 is 20% to 25%; this level increases to 50% by ages 75 to 80.^ 3 ^ Limited data suggest that less than 1% of small adenomatous polyps (smaller than 1 cm in size) will eventually develop into cancer. Of large polyps (larger than 1 cm in size), about 10% will become malignant within 10 years and about 25% after 20 years.^ 4 ^ Our current understanding of the biology of colorectal neoplasia suggests that most (more than 80%) of colorectal cancers arise from precancerous adenomatous polyps ("adenomas").

## Risk Factors for Colorectal Cancer

More than 60% of colorectal cancers occur in persons at average risk. Table 1 shows the relative risk of colorectal cancer for persons with certain characteristics. Approximately 20% of colorectal cancer cases occur among patients with a family history of colorectal cancer in a first-degree relative.^ 5 ^ In an analysis of 2 large cohorts involving more than 840,000 patient-years of follow-up, a family history of colorectal cancer was associated with a significant increase in risk in younger persons (1.7- to 4-fold increase between ages 40 and 60) but not with a significantly increased risk for persons older than age 60; risk was higher in persons with more than 1 affected relative.^ 6 ^ Six percent of colon cancers occur among persons with uncommon hereditary syndromes (e.g., familial adenomatous polyposis [FAP] or hereditary nonpolyposis colorectal cancer [HNPCC]) that confer a high risk of colorectal cancer. Persons with longstanding ulcerative colitis are at increased risk, as are persons with a history of large adenomatous polyps or colorectal cancer.^3,7^ Adenomatous polyps diagnosed in a first-degree relative before age 60 increases the risk of colorectal cancer (relative risk [RR]=1.78; 95% confidence interval [CI] 1.18 - 2.67).^ 8 ^ A prior diagnosis of endometrial or ovarian cancer also conveys increased risk, particularly for cancers occurring below age 50; a history of breast cancer increases risk only slightly, if at all.^9-11^, ^12,12,13,13^

Table 1. Relative Risk of Colorectal Cancer

Risk Factors | Relative Risk (95% CI)
Family history of colorectal cancer in a first-degree relative before age 60^ 3 ^ | 1.7 - 4.0*
Family history of adenomatous polyps in a first-degree relative before age 60^ 8 ^ | 1.8 (1.2, 2.7)
Personal history of breast cancer^ 9 ^ | 1.1 (1.0, 1.2)
Personal history of endometrial cancer ^12,13^
Diagnosis before age 50 | 3.4 (2.7, 4.2)†
Diagnosis age 50-64 | 0.93 (1.2, 1.8)
Personal history of ovarian cancer^12,13^
Diagnosis before age 50 | 3.7 (2.7, 4.8)
Diagnosis age 50-64 | 1.5 (1.2, 1.8)
*For patients age 40-60; older patients appear to have lower risk. † 95% confidence interval CCI.

The relationship between diet and colon cancer has been the subject of extensive epidemiologic research. Numerous observational studies have examined whether certain dietary elements are associated with an increased or decreased incidence of colon cancer or adenomatous polyps.^ 14 ^ Diets low in fat and red meat, and high in fiber and fruits and vegetables, have been associated with lower risks of colorectal cancer, but no evidence shows that changes in diet affect the subsequent rate of new cancers. High levels of physical activity are also associated with lower rates of colorectal cancers but, again, it is unclear if this relationship is causal or if it is confounded by other factors.^ 15 ^ A full examination of the observational evidence regarding the relationship between dietary functions or physical activity and colorectal cancer is beyond the scope of this paper.

## Prior Task Force Recommendations

In 1996 the USPSTF recommended screening for colorectal cancer with fecal occult blood testing (FOBT), sigmoidoscopy, or both tests.^ 16 ^ The USPSTF did not recommend for or against other means of screening (digital rectal examination [DRE], barium enema, colonoscopy) on the grounds that evidence was insufficient. They also recommended that FOBT be performed yearly but did not specify an interval for sigmoidoscopy.

To update the 1996 review and provide the scientific evidence for the USPSTF to make new recommendations, we undertook a systematic review of screening for colorectal cancer in average-risk adults. Related questions, such as screening of higher-risk patients, surveillance of patients with previous polyps or cancers, or diagnosis of patients with colon-related symptoms, are mentioned briefly but were not reviewed for this report.