# Appendix D Ongoing and Pending Trials

Principal investigators | Location | Population | Approximate size | Investigations | Outcomes | Status as of 2007
KQ1: Screening outcomes
Audrey Burnam, PhD Lisa Jaycox, PhD | US | 13- to 17-year-olds receiving care at a participating primary care physician office; half with major depression diagnosis, half with no detectable mental disorder | 800 | 1) Impact of depression on adolescent and family functioning,; 2) Effect of diagnosis feedback vs. educational brochure on care received, and; 3) Barriers and facilitators to receiving appropriate care | 1) Baseline and followup assessments; 2) Receipt of care and satisfaction; 3) Descriptive analysis | In progress
KQ2: Screening efficacy
Lise Bergeron, PhD | Canada | 6- to 11-year-olds from both general and clinical populations | 600 | Dominic Interactive | Reliability and validity | Submitted for publication
Kelly J. Kelleher, MD, MPH | US | Children aged 11 and older | 5,900 | Trial of Automated Risk Appraisal for Adolescents (TARAA) vs. usual care | Care comparison | Completion expected August 2008
KQ3: Screening harms
KQ4: Treatment efficacy, SSRIs
Forest Laboratories | US | 12- to 17-year-olds with diagnosis of MDD | Not available | Escitalopram vs. placebo | CDRS-R, CGI-I, CGAS | Recruitment completed
KQ4: Treatment efficacy, psychotherapy
Laura Mufson, PhD | New York | Females 12 to 18 years old with diagnosis of MDD, Dysthymic Disorder, Depressive Disorder NOS, or Adjustment Disorder with depressed mood in school-based health clinics | 125 | Group IPT vs. TAU | Depressive symptoms (HRSD and CES-D), overall impairment (C-GAS), social functioning (SAS-SR) | In progress
Kevin Stark, PhD | Austin | Females 9 to 13 years old with diagnosis of depressive disorder, including MDD, dysthymia, depression NOS, and MDD in partial remission | Currently 128, with screening of one cohort remaining | School-based CBT, CBT with parent training component, minimal contact control condition | Depressive symptoms (CDI, BDI-Y, K-SADS, CBCL), GAS, cognition, family functioning, educational functioning | Results expected in 2008
Robin Weersing, PhD | Pennsylvania | 8- to 17-year-olds | 60 | Eight sessions of CBT vs. community referral | Symptoms of depression and anxiety; ratings of global improvement | Data collection complete, expect to submit for publication end of 2007
KQ5: Treatment harms
Enid M. Hunkeler, MA | California | Children and adolescents who were members of the Kaiser Permanente Medical Care Program from 1995 through 2003 | 800,000 | Antidepressant medications and suicidal behavior | Completed suicides and suicide attempts | Manuscript in progress
Onur N. Karayal, MD, MPH John S. March, MD, MPH | US and Canada | 7- to 17-year-olds enrolled in the Child and Adolescent Psychiatry Trials Network with a diagnosis of an anxiety disorder, depressive disorder, eating disorder or obsessive-compulsive disorder and who were prescribed an SSRI or SNRI | 2,420 | Risks and benefits of treatment with an SSRI or SNRI | DPS-IV and PAERS | Completion expected February 2010
Kelly J. Kelleher, MD, MPH | US | Youth, adults, and older adults | Not available | Relationships among antidepressant use, suicide, and suicidality | Bayesian hierarchical models | Completion expected June 2011

MDD-Major Depressive Disorder; NOS-not otherwise specified; HRSD-Hamilton Rating Scale for Depression; CES-D-Center for Epidemiological Studies-Depression Scale; C-GAS-Global Assessment Scale for Children; SAS-SR-Social Adjustment Scale-Self-Report; IPT-Interpersonal Psychotherapy; SSRI-selective serotonin reuptake inhibitor; CBT-Cognitive-Behavioral Therapy; CDRS-R-Children's Depression Rating Scale-Revised; Kiddie-SADS-Kiddie Schedule for Affective Disorders and Schizophrenia; NOS-not otherwise specified; SNRI-serotonin-norepinephrine reuptake inhibitor; DPS-IV-DISC Predictive Scales; PAERS-Pediatric Adverse Event Rating Scale