# Appendix C

Table C1 Studies Excluded from the Review for Key Question 1

Key Question 1: Does screening for depression among children and adolescents in the primary care setting improve health outcomes?
Reference | Reason for exclusion*
Asarnow JR, Jaycox LH, Anderson M. Depression among youth in primary care models for delivering mental health services. Child Adolesc Psychiatr Clin N Am. 2002;11:477–97, viii. | Does not focus on depression screening or treatment or harms of either
Asarnow JR, Jaycox LH, Duan N et al. Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA. 2005;293:311–319. | Does not focus on depression screening or treatment or harms of either
Borowsky IW, Mozayeny S, Ireland M. Brief psychosocial screening at health supervision and acute care visits. Pediatrics. 2003;112:129–133. | Does not report outcomes listed in inclusion criteria
Chatterji P, Caffray CM, Crowe M, Freeman L, Jensen P. Cost assessment of a school-based mental health screening and treatment program in New York City. Mental Health Services Research 2004; 6(3):155–66. | Does not meet criteria for study design
Christensen H, Griffiths KM, Korten A. Web-based cognitive behavior therapy: analysis of site usage and changes in depression and anxiety scores. J Med Internet Res. 2002;4:e3. | Does not focus on depression screening or treatment or harms of either
Cuijpers P, van Straten A, Smits N, Smit F. Screening and early psychological intervention for depression in schools : Systematic review and meta-analysis. Eur Child Adolesc Psychiatry 2006; 15(5):300–7. | Does not meet criteria for study design
Geddes J, Butler R. Depressive disorders. Clin Evid. 2002;951–973. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Gilbody S, House AO, Sheldon TA. Screening and case finding instruments for depression. Cochrane Database of Systematic Reviews. 2006. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Hazell P. Depression in children and adolescents. Evid Based Ment Health. 2003;6:103–104. | Does not meet criteria for study design
Klein DN, Dougherty LR, Olino TM. Toward guidelines for evidence-based assessment of depression in children and adolescents. J Clin Child Adolesc Psychol. 2005;34:412–432. | Does not meet criteria for study design
Moor S, Ann M, Hester M et al. Improving the recognition of depression in adolescence: Can we teach the teachers? J Adolesc. 2007; 30(1):81–95. | Does not focus on depression screening or treatment or harms of either
Murphy K. Recognizing depression in children. Nurse Practitioner 2004;29(9):18–29; quiz 30–1. | Does not focus on depression screening or treatment or harms of either
Nelms BC. Childhood depression: Be on the alert. Journal of Pediatric Health Care 2003;17(4):161–2. | Does not focus on depression screening or treatment or harms of either
Pignone, M. P., Gaynes, B. N., Rushton, J. L., Mulrow, C. D., Orleans, C. T., Whitener, B. L., Mills, C., and Lohr, K. N. Screening for Depression. i-D-83. 2002. Rockville, MD, Agency for Healthcare Research and Quality. | Used as a source document only
Smith MS, Mitchell J, McCauley EA, Calderon R. Screening for anxiety and depression in an adolescent clinic. Pediatrics. 1990;85:262–266. | Does not report outcomes listed in inclusion criteria
Van Lang ND, Ferdinand RF, Verhulst FC. Predictors of future depression in early and late adolescence. Journal of Affective Disorders. 2007;97:137–144. | Does not meet criteria for study design
Weeks SK, Anderson MA, Harmon LS, Michaels TK. Getting inside depression and suicide ideation. Nursing Management 2004;35(10):42–6. | Does not meet criteria for study design
Winter LB, Steer RA, Jones-Hicks L, Beck AT. Screening for major depression disorders in adolescent medical outpatients with the Beck Depression Inventory for Primary Care. J Adolesc Health. 1999;24:389–394. | Does not focus on depression screening or treatment or harms of either
Zimmerman M, Posternak MA, Chelminski I. Derivation of a definition of remission on the Montgomery-Asberg depression rating scale corresponding to the definition of remission on the Hamilton rating scale for depression. J Psychiatr Res. 2004;38:577–582. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Zuckerbrot RA, Jensen PS. Improving recognition of adolescent depression in primary care. Archives of Pediatrics & Adolescent Medicine 2006; 160(7):694–704. | Does not meet criteria for study design

* See Appendix B, Table B2 for more detailed exclusion criteria

Table C2 Evidence Table for Screening Accuracy for Depression in Children and Adolescents: Key Question 2

Study ID | Setting | Prevalence of depression | Number of patients (CONSORT-type numbers) Exclusions (# and reason) | Patient characteristics | Primary screening test characteristics | Reference/Gold Standard | Sensitivity (95% CI) | Specificity (95% CI) | Positive Predictive Value | Negative Predictive Value | Other performance characteristics | USPSTF Quality Score | Applicability
Canals, 2001^1^ Canals, 1997^2^ Canals, 1995^3^ | Location: Urban Spain, school setting Target population: Original sample: boys aged 11 and girls aged 10 Current sample: all of original sample who could be found and consented (304/579) Selection method: All age-eligible children per municipal census recruited and completed assessments through schools | 3.4% MDD (calc) 6.2% Dysthymia (calc) (per diagnostic interview, time frame NR) | 579 original sample 304 found/recruited for current study 290 completed full baseline assessment Exclusions: 579–304=275 not found or did not consent | Mean age: 18 (range 17.5–18.5) Female: 49.7% of recruited (calc) Ethnicity: NR SES: “above average” Risk factors: NR | Test: BDI Screening cutoff: ≥10, 11, 14, 16 | Schedules for Clinical Assessment in Neuropsychiatry (SCAN) | 10: 100% 11: 90% 14: 90% 16: 90% (MDD only) | 10: 81.8% 11: 86% 14: 91.8% 16: 96% (MDD only) | 10: 16.9% 11: 20% 14: 29% 16: 47% (MDD only) | 10: 100% 11: 99.5% 14: 99% 16: 99.6% (MDD only) | NR | Fair | Fair. Participants still available for contact eight years after original sample more likely to be female, parents have higher levels of education and SES, but probably not problematic enough to disqualify.
Winter, 1999^4^ | Location: Outpatient pediatric practice in suburban area in New Jersey Target population: Adolescents (ages 12–17) Selection method: Adolescents attending a health maintenance appointment were recruited, all enrolled except three girls who refused | 11% current MDD (calc) (per diagnostic interview) | 103 approached, 100 enrolled (50 girls, 50 boys) Exclusions: none | Mean age: 13.9 (SD 1.6) Female: 50% Ethnicity: 73% White, 19% Black, 4% Hispanic, 4% Asian SES: “middle class” Risk factors: NR | Test: BDI-PC Screening cutoff: ≥4 | Mood Module of PRIME-MD administered by pediatricians | 91% (MDD) | 91% (MDD) | 55.6% (MDD) | 98.8% (MDD) | AUC=0.98 | Fair—not sure why it took so long to recruit the subjects, less-than-ideal reference standard (kappa=0.63 reported in another study using this study's methodology) | Good-Excellent. Question why it took so long to recruit these cases. Few adolescents having health maintenance visits? If so, generalizability may be more limited, despite primary care setting.
Patton, 1999^5^ | Location: Schools in Victoria, Australia Students of Government, Catholic, and Independent schools Target population: Forty-five schools selected with probability proportional to number of year nine students in each of three types of schools. Two classes randomly selected from each school Selection method: All CIS-R-positive youth and random sample of CIS-R-negative students selected for diagnostic interview | 3.8% current depression (per screener) 6.2% current MDD (per diagnostic interview) 12.1% six months previous (per diagnostic interview) | 2,032 selected 1,729 completed screener 65 positive screen, attempted diagnostic interview 53 positive screen, completed diagnostic interview 105 negative screen, completed diagnostic interview Exclusions: NR | Mean age: 15.7 (SD 0.5) Female: 53% Ethnicity: NR SES: NR Risk factors: NR | Test: CIS-R Screening cutoff: NR | CIDI | 18% (depressive episode) (used inverse probability weighting based on likelihood of selection/participation since only followed up on subset) | 97% (depressive episode) (used inverse probability weighting based on likelihood of selection/participation since only followed up on subset) | 49% (depressive episode) | 91% (depressive episode) | NR | Fair—delay between screen and reference standard problematic but not fatal | Fair
Johnson, 2002^6^ | Location: Primary care and school nurses' offices in CA, OH, NJ, and NY; rural, urban, and suburban sites Target population: 13- to 18-year-old English-speaking youth with at least 9 years of education Selection method: CA: youth with recent primary care visit within specified network were invited via letter OH, NJ, NY: youth invited by their providers and given baseline questionnaire packet to mail in; only those whose diagnostic interview completed within 18 days included in analysis (162/403 completed diagnostic interviews) | 9.4% MDD (per diagnostic interview, no time-frame specified) | CA: 900 invited 285 parental consent returned 254 youth completed baseline questionnaire 241 completed diagnostic interview within one week OH, NJ, NY: 442 invited and completed baseline questionnaire 403 completed diagnostic interview 162 diagnostic interview within 18 days Total sample: 241+162=403 Exclusions: Evidence of cognitive impairment (# NR) | Mean age: 15.9 (SD 1.2) Female: 63.3% Ethnicity: 77.2% White, 4.2% African American, 12.4% Hispanic SES: NR Risk factors: NR | Test: PHQ-A Screening cutoff: NR - used “diagnostic algorithm” | Diagnostic interview with mental health professional | 73% (MDD) | 94% (MDD) | 56% (MDD) | 97% (MDD) | NR | Fair—dropped 60% of non-CA site participants from analysis because lag between screen and reference test >18 days; no reliability information on this form of PHQ | Fair. Excellent except for the large nonrandom group of the OH/NJ/NY sample dropped from analysis, which may have biased results
Barrera, 1988^7^ | Location: Private secondary school, assume in AZ (location of authors) Target population: Students ages 12–17 Selection method: NR | 10.2% (per diagnostic interview) | 49 (other CONSORT numbers NR) Exclusions: NR | Mean age: 14.9 (range 12–18) Female: 55% Ethnicity: NR SES: NR Risk factors: NR | Test: BDI Screening cutoff: 6, 11, 16, 21, 26 | Child Assessment Schedule | 6: 100% 11: 100% 16: 100% 21: 80% 26: 80% (major depressive episode) | 6: 52.3% 11: 77.3% 16: 93.2% 21: 95.5% 26: 97.7% (major depressive episode) | NR | NR | False positive/negative: 6: 42.9% / 0% 11: 20.4% / 0% 16: 6.1% / 0% 21: 4.1% / 2.0% 26: 2.0% / 2.0% (major depressive episode) | Fair | Fair. No information about refusal rate, drop-out between screen and interview, so could be problematic but we wouldn't be able to tell
Whitaker, 1990^8^ | Location: Schools in NJ Target population: Entire enrollment of grades 9–12 in one NJ semi-rural county Selection method: All students in private or public schools invited for screening, random stratified (based on screening results) sample selected for interview | 4.0% (weighted prevalence for population per diagnostic interview) | 5,596 identified as eligible 5,108 completed screen 468 selected for interview 356 completed interview Exclusions: None reported, likely had none | Age: 92% ages 14–17 Female: 49.8% Ethnicity: 94% White SES: 42% mothers and 34% fathers high school graduates and no more schooling Risk factors: NR | Test: BDI Screening cutoff: 16 | Semi-structured diagnostic interview, depression section modeled after Columbia Clinical Interview | 76.9% (lifetime MDD) | 64.8% (lifetime MDD) | NR | NR | NR | Fair—due to apparent long time span between screen and interview, which they handled by assessing lifetime MDD | Fair
Garrison, 1991^9^ Garrison, 1990^10^ | Location: Middle and high schools in southeastern metropolitan school district Target population: Students in or transferring to designated schools for middle or high school Selection method: Earliest assessment, at 7th, 8th, or 9th grade | 8.2% males 8.7% females (per diagnostic interview) | 2,488 completed screening 2,465 data presented (NR why 23 cases dropped) 348 selected for diagnostic interview 332 completed diagnostic interview Exclusions: None reported, likely had none | Age: 93% ages 12–14 Female: 57% Ethnicity: 75% White, 25% African American SES: 36% fathers completed high school and no further schooling Risk factors: NR | Test: CES-D Screening cutoff: 12, 16, 20, 22 | K-SADS | Males: 12: 85% 16: 59% 20: 19% 22: 18% Females: 12: 84% 16: 83% 20: 84% 22: 83% (MDD) | Males: 12: 49% 16: 66% 20: 78% 22: 83% Females: 12: 38% 16: 53% 20: 70% 22: 77% (MDD) | Males: 12: 13% 16: 13% 20: 7% 22: 9% Females: 12: 11% 16: 14% 20: 21% 22: 25% (MDD) | NR | AUC 0.61 (males) 0.77 (females) | Fair—fairly high attrition rate, time between screen and interview NR | Fair
Roberts, 1991^11^ | Location: High schools in west-central OR Target population: High school students Selection method: Random sample of nine schools in five communities (stratified by school); rural oversampled to get equal proportion urban/rural | NR | 1,710 completed at least one of screeners and K-SADS data Exclusions: Parental refusal (# NR) | Mean age: 16.6 Female: 52.9% Ethnicity: 91.1% White SES: 42.8% fathers and 30.1% mothers completed 4+ years college Risk factors: NR | Test: BDI and CESD Screening cutoff: BDI: 11 for total sample, 11 for females, 15 for males CESD: 24 for total sample, 24 for females, 22 for males | K-SADS | BDI: 83.7 CESD: 83.7 (Current MDD) | BDI: 80.9 CESD: 75.2 (Current MDD) | BDI: 10.2 CESD: 8.0 (Current MDD) | BDI: 99.5 CESD: 99.4 (Current MDD) | NR | Fair | Fair. Only 61% of recruited youth participated
Goodman, 2003^12^ | Location: UK Target population: General population of 5- to 15-year-olds Selection method: Sample selected from child benefit records, which represents 98% of British children | NR | 10,438 recruited 7,984 (76%) had complete data: parent-, teacher-, and self-report Exclusions NR, likely had none | Mean age: 10.2 Female: 50.3% Ethnicity: NR SES: NR Risk factors: NR | Test: SDQ Screening cutoff: No cut-off specified, used scoring algorithm for anxiety-depressive disorders to categorize as unlikely, possible, or probable. “Probable” was considered positive screen, “unlikely” and “possible” were considered negative screens. | Clinical raters reviewed parent and child interview records, teacher questionnaires and assigned diagnosis (but did not review SDQ data) | 5- to 10-year-olds Parent-report: 53.9% 11- to 15-year-olds Self-report: 33.3% Parent-report: 44.4% Self+Parent: 63.0% (any depressive disorder) | NR | NR | NR | NR | Fair—did not provide specificity, instrument measured probability of depression or anxiety diagnosis | Fair-Good, but they used teacher report which would not be feasible for primary care

SES-socio-economic status; MDD-Major Depressive Disorder; calc-calculated; NR-not reported; SD-standard deviation; BDI-Beck Depression Inventory; BDI-PC- Beck Depression Inventory for Primary Care; PRIME-MD-Primary Care Evaluation of Mental Disorders; AUC-Area under the curve; CIS-R-Clinical Interview Schedule; CIDI-Composite International Diagnostic Interview; PHQ-A- Patient Health Questionnaire for Adolescents; CESD-Center for Epidemiologic Studies Depression Scale; CESD-C-Center for Epidemiologic Studies Depression Scale for Children; K-SADS-Kiddie Schedule for Affective Disorders and Schizophrenia; psych-psychiatric; ped-pediatric; SMFQ-Short Mood and Feeling Questionnaire; DISC- Diagnostic Interview Schedule for Children; DSM-Diagnostic and Statistical Manual of Mental Disorders; SDQ-Strengths and Difficulties Questionnaire; MFQ-C/P- Mood and Feeling Questionnaire, Child and Parent versions

References

1 Canals Josepa, Blade J, Carbajo G, Domenech-Llaberia E. The Beck Depression Inventory: Psychometric characteristics and usefulness in nonclinical adolescents. European Journal of Psychological Assessment. 2001;17(1):63-68.

2 Canals J, Domenech E, Carbajo G, Blade J. Prevalence of DSM-III-R and ICD-10 psychiatric disorders in a Spanish population of 18-year-olds. Acta Psychiatr Scand. 1997;96:287-294. [pmid: 9350958].

3 Canals J, Marti-Henneberg C, Fernandez-Ballart J, Domenech E. A longitudinal study of depression in an urban Spanish pubertal population. Eur Child Adolesc Psychiatry. 1995;4:102-111. [pmid: 7796248].

4 Winter LB, Steer RA, Jones-Hicks L, Beck AT. Screening for major depression disorders in adolescent medical outpatients with the Beck Depression Inventory for Primary Care. J Adolesc Health. 1999;24:389-394. [pmid: 10401966].

5 Patton GC, Coffey C, Posterino M, Carlin JB, Wolfe R, Bowes G. A computerised screening instrument for adolescent depression: population-based validation and application to a two-phase case-control study. Social Psychiatry Psychiatric Epidemiology. 1999;34(3):166-72.

6 Johnson JG, Harris ES, Spitzer RL, Williams JB. The patient health questionnaire for adolescents: validation of an instrument for the assessment of mental disorders among adolescent primary care patients. J Adolesc Health. 2002;30:196-204. [pmid: 11869927].

7 Barrera M Jr, Garrison-Jones CV. Properties of the Beck Depression Inventory as a screening instrument for adolescent depression. J Abnorm Child Psychol. 1988;16:263-273. [pmid: 3403810].

8 Whitaker A, Johnson J, Shaffer D, et al. Uncommon troubles in young people: prevalence estimates of selected psychiatric disorders in a nonreferred adolescent population. Arch Gen Psychiatry. 1990;47:487-496. [pmid: 2331210].

9 Garrison CZ, Addy CL, Jackson KL, McKeown RE, Waller JL. The CES-D as a screen for depression and other psychiatric disorders in adolescents. J Am Acad Child Adolesc Psychiatry. 1991;30:636-641. [pmid: 1890099].

10 Garrison CZ, Jackson KL, Marsteller F, McKeown R, Addy C. A longitudinal study of depressive symptomatology in young adolescents. J Am Acad Child Adolesc Psychiatry. 1990;29:581-585. [pmid: 2387792].

11 Roberts RE, Lewinsohn PM, Seeley JR. Screening for adolescent depression: a comparison of depression scales. J Am Acad Child Adolesc Psychiatry. 1991;30:58-66. [pmid: 2005065].

12 Goodman R, Ford T, Simmons H, Gatward R, Meltzer H. Using the Strengths and Difficulties Questionnaire (SDQ) to screen for child psychiatric disorders in a community sample. International Review of Psychiatry. 2003;15(12):166-72. May. [pmid: 12745328].

Table C3 Studies Excluded from the Review for Key Question 2

Key Question 2: Are depression screening instruments for children and adolescents accurate in identifying depression in primary care or school-based clinics?
Reference | Reason for exclusion*
Abela, John R. Z., Zuroff, David C., Ho, Moon Ho, Adams, Philippe, and Hankin, Benjamin L. Excessive Reassurance Seeking, Hassles, and Depressive Symptoms in Children of Affectively Ill Parents: A Multiwave Longitudinal Study. Journal of Abnormal Child Psychology 2006;34(2), 171–187. | Does not focus on depression screening or treatment or harms of either
Ailey SH. Screening adolescents with mental retardation for depression. Journal of School Nursing 2000; 16(1):6–11. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Ambrosini PJ, Metz C, Bianchi MD, Rabinovich H, Undie A. Concurrent validity and psychometric properties of the Beck Depression Inventory in outpatient adolescents. J Am Acad Child Adolesc Psychiatry. 1991;30:51–57. | Conducted exclusively in high-risk populations
Angold A, Costello EJ, Messer SC, Pickles A, Winder F, Silver D. Development of a short questionnaire for use in epidemiological studies of depression in children and adolescents. Int J Methods Psychiatr Res. 1995;5:237–249. | Does not meet criteria for population
Aragones E, Pinol JL, Labad A, Folch S, Melich N. Detection and management of depressive disorders in primary care in Spain. International Journal of Psychiatry in Medicine 2004;34(4):331–43. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Arroll, Bruce, Khin, Natalie, and Kerse, Ngaire. Screening for depression in primary care with two verbally asked questions: Cross sectional study. BMJ: British Medical Journal 2003;327(7424), 1144–1146. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Baillie AJ. Predictive gender and education bias in Kessler's psychological distress Scale (k10). Social Psychiatry & Psychiatric Epidemiology 2005;40(9):743–8. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Bauman, Sheri, Merta, Rod, and Steiner, Robert. Further validation of the adolescent form of the SASSI. Journal of Child & Adolescent Substance Abuse 1999;9(1), 51–71. | Does not focus on depression screening or treatment or harms of either
Beck AT, Steer RA, Ball R, Ciervo CA, and Kabat M. Use of the Beck Anxiety and Depression Inventories for Primary Care with medical outpatients. Psychological Assessment 4, 211–219. 1997. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Bennett DS, Ambrosini PJ, Kudes D, Metz C, Rabinovich H. Gender differences in adolescent depression: do symptoms differ for boys and girls? Journal of Affective Disorders 2005;89(1–3):35–44. | Does not focus on depression screening or treatment or harms of either
Bidaut-Russell, Michelle, Valla, Jean Pierre, Thomas, Jean M., Begeron, Lise, and Lawson, Erma. Reliability of the Terry: A mental health cartoon-like screener for African-American children. Child Psychiatry & Human Development 1998; 28(4), 249–263. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Biederman J, Monuteaux MC, Kendrick E, Klein KL, Faraone SV. The CBCL as a screen for psychiatric comorbidity in paediatric patients with ADHD. Archives of Disease in Childhood 2005;90(10):1010–5. | Conducted exclusively in high-risk populations
Borowsky IW, Mozayeny S, Ireland M. Brief psychosocial screening at health supervision and acute care visits. Pediatrics. 2003;112:129–133. | Does not report outcomes listed in inclusion criteria
Brooks SJ KSK. The Kutcher Adolescent Depression Scale: assessment of its evaluative properties over the course of an 8-week pediatric pharmacotherapy trial. Journal of child and adolescent psychopharmacology 2003;13(3):337–49. | Does not meet criteria for study design
Brugha, T. S., Bebbington, P. E., Jenkins, R., Meltzer, H., Taub, N. A., Janas, M., and Vernon, J. Cross validation of a general population survey diagnostic interview: A comparison of CIS-R with SCAN ICD-10 diagnostic categories. Psychological Medicine 1999;29(5), 1029–1042. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Boyd JH, Weissman MM, Thompson WD, Myers JK. Screening for depression in a community sample. Understanding the discrepancies between depression symptom and diagnostic scales. Arch Gen Psychiatry. 1982;39:1195–1200. | Does not meet population criteria
Cairney J, Veldhuizen S, Wade TJ, Kurdyak P, Streiner DL. Evaluation of 2 measures of psychological distress as screeners for depression in the general population. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie. 2007;52:111–120 | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Canning EH, Kelleher K. Performance of screening tools for mental health problems in chronically ill children. Arch Pediatr Adolesc Med. 1994;148:272–278. | Conducted exclusively in high-risk populations
Caplan, Rochelle, Siddarth, Prabha, Gurbani, Suresh, Hanson, Rebecca, Sankar, Ramen, and Shields, W. Donald. Depression and Anxiety Disorders in Pediatric Epilepsy. Epilepsia 2005; 46(5), 720–730. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Center for Epidemiological Studies. Innovations in clinical practice: Focus on children & adolescents. 105–107. 2003. | Does not focus on depression screening or treatment or harms of either
Chorpita, Bruce F., Moffitt, Catherine E., and Gray, Jennifer. Psychometric properties of the Revised Child Anxiety and Depression Scale in a clinical sample. Behaviour Research and Therapy 2005;43(3), 309–322. | Conducted exclusively in high-risk populations
Chrisman, Allan, Egger, Helen, Compton, Scott N., Curry, John, and Goldston, David B. Assessment of Childhood Depression. Child and Adolescent Mental Health 2006; 11(2), 111–116. | Does not meet criteria for study design
Christensen H, Griffiths KM, Korten A. Web-based cognitive behavior therapy: analysis of site usage and changes in depression and anxiety scores. J Med Internet Res. 2002;4:e3. | Does not focus on depression screening or treatment or harms of either
Comer JS, Kendall PC. High-end specificity of the children's depression inventory in a sample of anxiety-disordered youth. Depression & Anxiety 2005;22(1):11–9. | Conducted exclusively in high-risk populations
Cuffe SP, McKeown RE, Addy CL, Garrison CZ. Family and psychosocial risk factors in a longitudinal epidemiological study of adolescents. Journal of the American Academy of Child & Adolescent Psychiatry 2005;44(2):121–9. | Does not focus on depression screening or treatment or harms of either
Cuijpers P, van Straten A, Smits N, Smit F. Screening and early psychological intervention for depression in schools : Systematic review and meta-analysis. Eur Child Adolesc Psychiatry. 2006; 15(5):300–7. | Does not meet criteria for study design
Daviss, W. Burleson, Birmaher, Boris, Melhem, Nadine A., Axelson, David A., Michaels, Shana M., and Brent, David A. Criterion validity of the Mood and Feelings Questionnaire for depressive episodes in clinic and non-clinic subjects. Journal of Child Psychology and Psychiatry 2006;47(9), 927–934. | Does not meet criteria for population
de Ross, Raelene, Gullone, Eleonora, and Chorpita, Bruce F. The Revised Child Anxiety and Depression Scale: A psychometric investigation with Australian youth. Behaviour Change 2002;19(2), 90–101. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Dierker LC, Albano AM, Clarke GN et al. Screening for anxiety and depression in early adolescence. Journal of the American Academy of Child & Adolescent Psychiatry 2001;40(8):929–36. | Does not meet quality criteria: rate of participation different within strata, small final sample unlikely to be representative of primary care population
Fendrich M, Weissman MM, Warner V. Screening for depressive disorder in children and adolescents: validating the Center for Epidemiologic Studies Depression Scale for Children. Am J Epidemiol. 1990;131:538–551. | Does not meet population criteria
Friedman RJ and Butler LF. Development and validation of a test battery to assess childhood depression. 606-1533-44, 1-27. 6-15-1979. Ontario, Canada, The Ontario Institute for Studies in Education. Final Report to Health and Welfare, Canada. | Does not meet quality criteria: outcome assessment not blinded, inadequate reference standard
Gardner W, Lucas A, Kolko DJ, Campo JV. Comparison of the PSC-17 and alternative mental health screens in an at-risk primary care sample. Journal of the American Academy of Child & Adolescent Psychiatry. 2007;46:611–618. | Conducted exclusively in high-risk populations
Gardner W, Shear K, Kelleher KJ et al. Computerized adaptive measurement of depression: a simulation study. BMC Psychiatry. 2004;4:13. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Gardner, W., Murphy, M, and Childs, G. The PSC-17: a brief pediatric symptom checklist including psychosocial problem subscales: a report from PROS and ASPN. Ambulatory Child Health 1999;5, 225–236. | Does not report outcomes listed in inclusion criteria
Geddes J, Butler R. Depressive disorders. Clin Evid. 2002;951–973. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Goncalves, Bruno and Fagulha, Teresa. The Portuguese Version of the Center for Epidemiologic Studies Depression Scale (CES-D). European Journal of Psychological Assessment 2004;20(4), 339–348. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Gupta S, Crawford SG, Mitchell I. Screening children with asthma for psychosocial adjustment problems: a tool for health care professionals. J Asthma. 2006;43:543–548. | Conducted exclusively in high-risk populations
Hazell P. Depression in children and adolescents. Evid Based Ment Health. 2003;6:103–104. | Does not meet criteria for study design
Holcomb SS. Identification and treatment of depression. Nurse Pract. 2006;31:42–44. | Does not meet criteria for study design
Jellinek M, Little M, Murphy JM, Pagano M. The Pediatric Symptom Checklist. Support for a role in a managed care environment. Arch Pediatr Adolesc Med. 1995;149:740–746. | Does not report outcomes listed in inclusion criteria
Jellinek MS, Murphy JM, Burns BJ. Brief psychosocial screening in outpatient pediatric practice. J Pediatr. 1986;109:371–378. | Does not report outcomes listed in inclusion criteria
Jellinek MS, Murphy JM, Little M, Pagano ME, Comer DM, Kelleher KJ. Use of the Pediatric Symptom Checklist to screen for psychosocial problems in pediatric primary care: a national feasibility study. Arch Pediatr Adolesc Med. 1999;153:254–260. | Does not report outcomes listed in inclusion criteria
Jellinek MS, Murphy JM, Robinson J, Feins A, Lamb S, Fenton T. Pediatric Symptom Checklist: screening school-age children for psychosocial dysfunction. J Pediatr. 1988;112:201–209. | Does not report outcomes listed in inclusion criteria
Kanner AM, Dunn DW. Diagnosis and management of depression and psychosis in children and adolescents with epilepsy. J Child Neurol. 2004;19:Suppl-72. | Conducted exclusively in high-risk populations
Kashani JH, Sherman DD, Parker DR, Reid JC. Utility of the Beck Depression Inventory with clinic-referred adolescents. J Am Acad Child Adolesc Psychiatry. 1990;29:278–282. | Conducted exclusively in high-risk populations
Katon, Wayne J., Richardson, Laura, Russo, Joan, Lozano, Paula, and McCauley, Elizabeth. Quality of Mental Health Care for Youth with Asthma and Comorbid Anxiety and Depression. [References]. Medical Care 44[12], 1064–1072. 2006. | Conducted exclusively in high-risk populations
Killeen MR. Screening for major depression disorders in adolescent medical outpatients with the Beck Depression Inventory for Primary Care. Journal of Child & Family Nursing 2000;3(1):51–3. | Does not meet criteria for study design
Klein DN, Dougherty LR, Olino TM. Toward guidelines for evidence-based assessment of depression in children and adolescents. J Clin Child Adolesc Psychol. 2005;34:412–432. | Does not meet criteria for study design
Kresanov K, Tuominen J, Piha J, Almqvist F. Validity of child psychiatric screening methods. European Child & Adolescent Psychiatry 1998;7(2):85–95. | Does not focus on depression screening or treatment or harms of either
LeBlanc JC, Almudevar A, Brooks SJ, Kutcher S. Screening for adolescent depression: comparison of the Kutcher Adolescent Depression Scale with the Beck depression inventory. Journal of Child & Adolescent Psychopharmacology 12(2):113–26. 2002. | Conducted in population that is not comparable to primary care (e.g., high risk conditions not prevalent in primary care populations)
Matthey S, Petrovski P. The Children's Depression Inventory: error in cutoff scores for screening purposes. Psychological Assessment 2002;14(2):146–9. | Does not focus on depression screening or treatment or harms of either
McClusky J. Data need to be accurate when screening for depression in teenagers. BMJ 2005;331(7521):906. | Does not focus on depression screening or treatment or harms of either
McCue P, Buchanan T, Martin CR. Screening for psychological distress using internet administration of the Hospital Anxiety and Depression Scale (HADS) in individuals with chronic fatigue syndrome. British Journal of Clinical Psychology. 2006;45:4–98. | Conducted exclusively in high-risk populations
Means-Christensen AJ, Sherbourne CD, Roy-Byrne PP, Craske MG, Stein MB. Using five questions to screen for five common mental disorders in primary care: diagnostic accuracy of the Anxiety and Depression Detector. General Hospital Psychiatry 2006;28(2):108–18. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Monga S, Birmaher B, Chiappetta L et al. Screen for Child Anxiety-Related Emotional Disorders (SCARED): convergent and divergent validity. Depression & Anxiety 2000;12(2):85–91. | Does not focus on depression screening or treatment or harms of either
Moor S, Ann M, Hester M et al. Improving the recognition of depression in adolescence: Can we teach the teachers? J Adolesc. 2007; 30(1):81–95. | Does not focus on depression screening or treatment or harms of either
Murphy JM, Ichinose C, Hicks RC et al. Utility of the Pediatric Symptom Checklist as a psychosocial screen to meet the federal Early and Periodic Screening, Diagnosis, and Treatment (EPSDT) standards: a pilot study. J Pediatr. 1996;129:864–869. | Does not report outcomes listed in inclusion criteria
Murphy JM, Reede J, Jellinek MS, Bishop SJ. Screening for psychosocial dysfunction in inner-city children: further validation of the Pediatric Symptom checklist. J Am Acad Child Adolesc Psychiatry. 1992;31:1105–1111. | Does not report outcomes listed in inclusion criteria
Osman A, Kopper BA, Barrios F, Gutierrez PM, Bagge CL. Reliability and validity of the Beck depression inventory—II with adolescent psychiatric inpatients. Psychological Assessment 2004;16(2):120–32. | Does not meet criteria for study design
Pandya R, Metz L, Patten SB. Predictive value of the CES-D in detecting depression among candidates for disease-modifying multiple sclerosis treatment. Psychosomatics 2005;46(2):131–4. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Pavuluri M, Birmaher B. A practical guide to using ratings of depression and anxiety in child psychiatric practice. Current Psychiatry Reports 2004;6(2):108–16. | Does not meet criteria for study design
Pellegrino, Joseph F., Singh, Nirbhay N., and Carmanico, Sharon J. Concordance among three diagnostic procedures for identifying depression in children and adolescents with EBD. Journal of Emotional and Behavioral Disorders 1999;7(2), 118–127. | Does not meet setting criteria
Perreira, Krista M., eb-Sossa, Natalia, Harris, Kathleen Mullan, and Bollen, Kenneth. What Are We Measuring? An Evaluation of the CES-D Across Race/Ethnicity and Immigrant Generation. Social Forces 2005; 83(4), 1567–1602. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Pignone, M. P., Gaynes, B. N., Rushton, J. L., Mulrow, C. D., Orleans, C. T., Whitener, B. L., Mills, C., and Lohr, K. N. Screening for Depression. i-D-83. 2002. Rockville, MD, Agency for Healthcare Research and Quality. | Used as a source document only
Prescott CA, McArdle JJ, Hishinuma ES et al. Prediction of major depression and dysthymia from CES-D scores among ethnic minority adolescents. Journal of the American Academy of Child & Adolescent Psychiatry 1998;37(5):495–503. | Does not meet criteria for study design
Puertas G, Patel V, Marshall T. Are visual measures of mood superior to questionnaire measures in non-Western settings? Social Psychiatry & Psychiatric Epidemiology 2004; 39(8):662 -6. | Does not focus on depression screening or treatment or harms of either
Puura K, Almqvist F, Tamminen T et al. Psychiatric disturbances among prepubertal children in southern Finland. Social Psychiatry & Psychiatric Epidemiology 1998;33(7):310–8. | Does not focus on depression screening or treatment or harms of either
Revah-Levy A, Birmaher B, Gasquet I, Falissard B. The Adolescent Depression Rating Scale (ADRS): a validation study. BMC Psychiatry. 2007;7:2. | Conducted in population that is not comparable to primary care (e.g., high risk conditions not prevalent in primary care populations)
Reynolds, William M. and Mazza, James J. Reliability and validity of the Reynolds Adolescent Depression Scale with young adolescents. Journal of School Psychology 1998; 36(3), 295–312. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Reynolds, William M. The Reynolds Adolescent Depression Scale-Second Edition (RADS-2). 224–236. 2004. | Does not focus on depression screening or treatment or harms of either
Rieffe, Carolien, Terwogt, Mark Meerum, Petrides, K. V., Cowan, Richard, Miers, Anne C., and Tolland, Abigail. Psychometric properties of the Emotion Awareness Questionnaire for children. Personality and Individual Differences 43(1), 95–105. 2007. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Saylor CF, Finch AJ, Jr., Spirito A, Bennett B. The children's depression inventory: a systematic evaluation of psychometric properties. Journal of Consulting & Clinical Psychology 1984;52(6):955–67. | Does not report outcomes listed in inclusion criteria
Schubiner H, Tzelepis A, Wright K, Podany E. The clinical utility of the Safe Times Questionnaire. J Adolesc Health. 1994;15:374–382. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Shaffer D, Scott M, Wilcox H et al. The Columbia Suicide Screen: validity and reliability of a screen for youth suicide and depression. Journal of the American Academy of Child & Adolescent Psychiatry 2004;43(1):71–9. | Does not focus on depression screening or treatment or harms of either
Shemesh E, Yehuda R, Rockmore L et al. Assessment of depression in medically ill children presenting to pediatric specialty clinics. Journal of the American Academy of Child & Adolescent Psychiatry 2005;44(12):1249–57. | Conducted exclusively in high-risk populations
Sitarenios, Gill and Kovacs, Maria. Use of the Children's Depression Inventory. 267–298. 1999. | Does not focus on depression screening or treatment or harms of either
Snijders AH, Robertson MM, Orth M. Beck Depression Inventory is a useful screening tool for major depressive disorder in Gilles de la Tourette syndrome. Journal of Neurology, Neurosurgery & Psychiatry 2006;77(6):787–9. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Sorensen MJ, Frydenberg M, Thastum M, Thomsen PH. The Children's Depression Inventory and classification of major depressive disorder: validity and reliability of the Danish version. European Child & Adolescent Psychiatry 2005;14(6):328–34. | Conducted exclusively in high-risk populations
Taylor EH. Advances in the diagnosis and treatment of children with serious mental illness. Child Welfare 1998; 77(3):311–32. | Does not focus on depression screening or treatment or harms of either
Thapar A, McGuffin P. Validity of the shortened Mood and Feelings Questionnaire in a community sample of children and adolescents: a preliminary research note. Psychiatry Research 1998;81(2):259–68. | Does not meet criteria for study design
Timbremont B, Braet C, Dreessen L. Assessing depression in youth: relation between the Children's Depression Inventory and a structured interview. Journal of Clinical Child & Adolescent Psychology 2004;33(1):149–57. | Conducted exclusively in high-risk populations
Truman J, Robinson K, Evans AL et al. The Strengths and Difficulties Questionnaire: a pilot study of a new computer version of the self-report scale. Eur Child Adolesc Psychiatry. 2003;12:9–14. | Screening test results do not use a credible reference standard or test is not relevant to or feasible in primary care setting
Valla JP, Bergeron L, Berube H, Gaudet N, St-Georges M. A structured pictorial questionnaire to assess DSM-III-R-based diagnoses in children (6–11 years): development, validity, and reliability. J Abnorm Child Psychol. 1994;22:403–423. | Does not report outcomes listed in inclusion criteria
Valla JP, Bergeron L, Smolla N. The Dominic-R: a pictorial interview for 6- to 11-year-old children. Journal of the American Academy of Child & Adolescent Psychiatry 2000;39(1):85–93. | Does not focus on depression screening or treatment or harms of either
Volpe, Robert J. and DuPaul, George J. Handbook of psychoeducational assessment: Ability, achievement, and behavior in children. 357–387. 2001. | Does not focus on depression screening or treatment or harms of either
Weeks SK, Andreson MA, Harmon LS, Michaels TK. Getting inside depression and suicide ideation. One comprehensive screening approach targets patients 4 years and older. Holistic Nursing Practice. 2005;5–9. | Does not meet criteria for study design
White D, Leach C, Sims R, Atkinson M, Cottrell D. Validation of the Hospital Anxiety and Depression Scale for use with adolescents.[see comment]. British Journal of Psychiatry 1999;175:452 -4. | Conducted exclusively in high-risk populations
Wilcox H, Field T, Prodromidis M, Scafidi F. Correlations between the BDI and CES-D in a sample of adolescent mothers. Adolescence 1998;33(131):565–74. | Focus on identifying maternal depression
Wilhelm, Key, Kotze, Beth, Waterhouse, Merilyn, Hadzi-Pavlovic, Dusan, and Parker, Gordon. Screening for Depression in the Medically Ill: A Comparison of Self-Report Measures, Clinician Judgment, and DSM-IV Diagnoses. Psychosomatics: Journal of Consultation Liaison Psychiatry 20004;45(6), 461–469. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Yates P, Kramer T, Garralda E. Depressive symptoms amongst adolescent primary care attenders. Levels and associations. Soc Psychiatry Psychiatr Epidemiol. 2004;39:588–594. | Does not meet criteria for study design
Zimmerman M, Posternak MA, Chelminski I. Derivation of a definition of remission on the Montgomery-Asberg depression rating scale corresponding to the definition of remission on the Hamilton rating scale for depression. J Psychiatr Res. 2004;38:577–582. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Zuckerbrot RA, Jensen PS. Improving recognition of adolescent depression in primary care. Archives of Pediatrics & Adolescent Medicine 2006;160(7):694–704. | Used as a source document only

Table C4 Studies Excluded from the Review for Key Question 3

Key Question 3: What are the harms of screening?
Reference | Reason for exclusion*
Christensen H, Griffiths KM, Korten A. Web-based cognitive behavior therapy: analysis of site usage and changes in depression and anxiety scores. J Med Internet Res. 2002;4:e3. | Does not focus on depression screening or treatment or harms of either
Geddes J, Butler R. Depressive disorders. Clin Evid. 2002;951–973. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Gould MS, Marrocco FA, Kleinman M et al. Evaluating iatrogenic risk of youth suicide screening programs: a randomized controlled trial. JAMA 2005;293(13):1635–43. | Does not focus on depression screening or treatment or harms of either
Hazell P. Depression in children and adolescents. Evid Based Ment Health. 2003;6:103–104. | Does not meet criteria for study design
Klein DN, Dougherty LR, Olino TM. Toward guidelines for evidence-based assessment of depression in children and adolescents. J Clin Child Adolesc Psychol. 2005;34:412–432. | Does not meet criteria for study design
Moor S, Ann M, Hester M et al. Improving the recognition of depression in adolescence: Can we teach the teachers? J Adolesc. 2007; 30(1):81–95. | Does not focus on depression screening or treatment or harms of either
Pignone, M. P., Gaynes, B. N., Rushton, J. L., Mulrow, C. D., Orleans, C. T., Whitener, B. L., Mills, C., and Lohr, K. N. Screening for Depression. i-D-83. 2002. Rockville, MD, Agency for Healthcare Research and Quality. | Used as source document only
Winter LB, Steer RA, Jones-Hicks L, Beck AT. Screening for major depression disorders in adolescent medical outpatients with the Beck Depression Inventory for Primary Care. J Adolesc Health. 1999;24:389–394. | Does not focus on depression screening or treatment or harms of either
Zimmerman M, Posternak MA, Chelminski I. Derivation of a definition of remission on the Montgomery-Asberg depression rating scale corresponding to the definition of remission on the Hamilton rating scale for depression. J Psychiatr Res. 2004;38:577–582. | Does not meet setting criteria

Table C5 Evidence Table of Randomized Controlled Trials for Efficacy and Adverse Effects of Psychotherapy in Treating Depression in Children and Adolescents

Table C6 Studies Excluded from the Review for Key Question 4

Key Question 4: Does the treatment of depression (SSRIs and/or psychotherapy) among screen-detected children and adolescents identified in primary care or comparable populations improve health outcomes?
Reference | Reason for exclusion*
Ambrosini PJ, Wagner KD, Biederman J et al. Multicenter open-label sertraline study in adolescent outpatients with major depression. Journal of the American Academy of Child & Adolescent Psychiatry 1999;38(5):566–72. | Does not meet criteria for study design
Ames D. Depression and the elderly. In: Dawson A, Tylee A, eds. Depression: Social and economic timebomb: strategies for quality care: proceedings of an international meeting. xv ed. London: BMJ; 2001:49–54. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Antidepressants for children and adolescents: an update. Harv Ment Health Lett. 2006;22:4–5. | Does not meet criteria for study design
Antidepressants for young people. Can Fam Physician. 2004;50:1648. | Does not meet criteria for study design
Apter, Alan, Kronenberg, Sefi, and Brent, David. Turning darkness into light: A new landmark study on the treatment of adolescent depression. Comments on the TADS study. European Child & Adolescent Psychiatry 2005;14(3), 113–116. | Does not meet criteria for study design
Asarnow JR, Jaycox LH, Duan N et al. Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA. 2005;293:311–319. | Relevance (QI or collaborative care intervention)
Asarnow, Joan Rosenbaum, Scott, Cynthia V., and Mintz, Jim. A combined cognitive-behavioral family education intervention for depression in children: A treatment development study. Cognitive Therapy and Research 2002;26(2), 221–229. | Does not meet quality criteria: lack of usable data, important aspects of study design not reported (e.g., adherence, attrition), no comparison of groups at baseline
Barbe, Remy P., Bridge, Jeffrey A., Birmaher, Boris, Kolko, David J., and Brent, David A. Lifetime History of Sexual Abuse, Clinical Presentation, and Outcome in a Clinical Trial for Adolescent Depression. (References). Journal of Clinical Psychiatry 2004;65(1), 77–83. | Conducted exclusively in high-risk populations
Barnhart WJ, Makela EH, Latocha MJ. SSRI-induced apathy syndrome: a clinical review. Journal of Psychiatric Practice. 2004;10:196–199. | Does not meet criteria for study design
Barrera, Maur, Chung, Joanna Y. Y., Greenberg, Mark, and Fleming, Carly. Preliminary investigation of a group intervention for siblings of pediatric cancer patients. Children's Health Care 2002;31(2), 131–142. | Conducted exclusively in high-risk populations
Baumgartner JL, Emslie GJ, Crismon ML. Citalopram in children and adolescents with depression or anxiety. Annals of Pharmacotherapy 2002;36(11):1692–7. | Does not meet criteria for study design
Bezchlibnyk-Butler K, Aleksic I, Kennedy SH. Citalopram—a review of pharmacological and clinical effects. J Psychiatry Neurosci. 2000;25:241–254. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Birmaher B, Brent D. Should we use antidepressants for the treatment of major depressive disorder in children and adolescents? Revista Brasileira de Psiquiatria. 2005;27:89–90. | Does not meet criteria for study design
Birmaher B. Clinical outcome after short-term psychotherapy for adolescents with major depressive disorder. Arch Gen Psychiatry. 2000;29–36. | Focus on treatment comparison, matching, or fine-tuning
Blockman M. Selective serotonin reuptake inhibitors in children with major depression. S Afr Med J. 2006;Suid-Afrikaanse:476–477. | Does not meet criteria for study design
Bower P, Garralda E, Kramer T, Harrington R, Sibbald B. The treatment of child and adolescent mental health problems in primary care: a systematic review. Fam Pract. 2001;18(4):373–382. | Does not focus on depression screening or treatment or harms of either
Bower P, Rowland N, Mellor Clark J, Heywood P, Godfrey C, Hardy R. Effectiveness and cost effectiveness of counselling in primary care. Cochrane Database of Systematic Reviews. 2006. | Does not focus on depression screening or treatment or harms of either
Boylan K, Romero S, Birmaher B. Psychopharmacologic treatment of pediatric major depressive disorder. Psychopharmacology (Berl). 2007; 191(1):27–38. | Does not meet criteria for study design
Braconnier A, Le CR, Cohen D. Paroxetine versus clomipramine in adolescents with severe major depression: a double-blind, randomized, multicenter trial. J Am Acad Child Adolesc Psychiatry. 2003;42:22–29. | Focus on treatment comparison, matching, or fine-tuning
Brent DA, Holder D, Kolko D et al. A clinical psychotherapy trial for adolescent depression comparing cognitive, family, and supportive therapy. Arch Gen Psychiatry. 1997;54:877–885. | Focus on treatment comparison, matching, or fine-tuning (comparative efficacy trial)
Bridge JA, Salary CB, Birmaher B, Asare AG, Brent DA. The risks and benefits of antidepressant treatment for youth depression. Annals of Medicine 2005;37(6):404–12. | Does not meet criteria for study design
Brown C. Factors associated with symptomatic improvement and recovery from major depression in primary care patients. General Hospital Psychiatry. 2000;242–250. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Burns BJ, Hoagwood K, Mrazek PJ. Effective treatment for mental disorders in children and adolescents. Clin Child Fam Psychol Rev. 1999;2:199–254. | Does not meet criteria for study design
Burton E, Stice E, Bearman SK, Rohde P. Experimental test of the affect-regulation theory of bulimic symptoms and substance use: a randomized trial. International Journal of Eating Disorders. 2007;40:27–36. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Butler, L. Miezitis S. Friedman R. & Cole E. The effect of two school-based intervention programs on depressive symptoms in preadolescents. American Educational Research Journal 1980;17:111–119. | Does not meet criteria for study design
Byford S H. Cost-effectiveness analysis of a home based social work intervention for children and adolescents who have deliberately poisoned themselves. The British journal of psychiatry : the journal of mental science. 1999; 174:56–62. | Does not focus on depression screening or treatment or harms of either
Carpenter, D. J., Lipschitz, A., Fong, R., Krulewicz, S., Wilkinson, C., and Davies, J. Is it appropriate to combine data from children and adolescents in pediatric MDD clinical trials? Poster presented at: New Clinical Drug Evaluation Unit annual meeting. 6-8-2005. Boca Raton, FL. | Does not meet criteria for study design
Carty, Jill A. An examination of the relative effectiveness of three cognitive behavioral group treatments for depression in an Australian treatment-resistant population. Dissertation Abstracts International: Section B: The Sciences and Engineering 2001;62(1-B), 539. | Does not meet setting criteria
Cecchini TB. An interpersonal and cognitive-behavioral approach to childhood depression: A school-based primary prevention study. Dissertation Abstracts International: Section B: The Sciences and Engineering. 1998;58:6803. | Focus on prevention of depression (either universal or among populations with risk factors)
Chabrol H. CBT versus supportive therapy for depression. Journal of the American Academy of Child & Adolescent Psychiatry. 2005;44:841–843. | Does not meet criteria for study design
Cheung AH, Emslie GJ, Mayes TL. Review of the efficacy and safety of antidepressants in youth depression. Journal of Child Psychology and Psychiatry. 2005;46:-754. | Used as source document only
Cheung AH, Emslie GJ, Mayes TL. The use of antidepressants to treat depression in children and adolescents. CMAJ. 2006;174:193–200. | Does not meet criteria for study design
Christensen H, Griffiths KM, Korten A. Web-based cognitive behavior therapy: analysis of site usage and changes in depression and anxiety scores. J Med Internet Res. 2002;4:e3. | Does not focus on depression screening or treatment or harms of either
Cipriani A, Brambilla P, Furukawa T et al. Fluoxetine versus other types of pharmacotherapy for depression. Cochrane Database of Systematic Reviews. 2006. | Focus on treatment comparison, matching, or fine-tuning
Clarke G, Debar L, Lynch F et al. A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. Journal of the American Academy of Child & Adolescent Psychiatry 2005;44(9):888–98. | Relevance (QI or collaborative care intervention)
Clarke G, Hawkins W, Murphy M, Sheeber L, Lewinsohn P, Seeley J. Targeted Prevention of Unipolor Depressive Disorder in an At-Risk Sample of High School Adolescents: A Randomized Trial of a Group Cognitive Intervention. American Academy of Child and Adolescent Psychiatric. 1995;34:312–321. | Focus on prevention of depression (either universal or among populations with risk factors)
Clarke G. Cognitive-behavioral treatment and prevention of adolescent depression. 2001 Annual Meeting of the American Psychiatric Association. 2001;2001–2010. | Does not meet criteria for study design
Clarke GN, Hornbrook M, Lynch F et al. A randomized trial of a group cognitive intervention for preventing depression in adolescent offspring of depressed parents. Arch Gen Psychiatry. 2001;58:1127–1134. | Focus on prevention of depression (either universal or among populations with risk factors)
Clarke GN, Hornbrook M, Lynch F et al. Group cognitive-behavioral treatment for depressed adolescent offspring of depressed parents in a health maintenance organization. J Am Acad Child Adolesc Psychiatry. 2002;41:305–313. | Conducted exclusively in high-risk populations
Cohen D. Should the use of selective serotonin reuptake inhibitors in child and adolescent depression be banned?. Psychotherapy & Psychosomatics. 2007;76:5–14. | Does not meet criteria for study design
Cohen JA. Treating traumatized children: current status and future directions. Journal of Trauma & Dissociation. 2005;6:109–121. | Does not focus on depression screening or treatment or harms of either
Committee on Safety of Medicines. Report of the CSM Expert Working Group on the Safety of Selective Serotonin Reuptake Inhibitor Antidepressants. ii-185. 2004. | Used as source document only
Committee on Safety of Medicines. Selective serotonin reuptake inhibitors (SSRIs) - overview of regulatory status and CSM advice relating to major depressive disorder (MDD) in children and adolescents: Summary of clinical trials. MHRA. 2005. 2-9-2007. | Used as source document only
Compton SN, Burns BJ, Egger HL, Robertson E. Review of the evidence base for treatment of childhood psychopathology: internalizing disorders. J Consult Clin Psychol. 2002;70(6):1240–1266. | Precedes search period
Compton SN, March JS, Brent D, Albano AM, Weersing R, Curry J. Cognitive-behavioral psychotherapy for anxiety and depressive disorders in children and adolescents: an evidence-based medicine review. J Am Acad Child Adolesc Psychiatry. 2004;43:930–959. | Used as source document only
Cornelius JR, Clark DB, Bukstein OG, Birmaher B, Salloum IM, Brown SA. Acute phase and five-year follow-up study of fluoxetine in adolescents with major depression and a comorbid substance use disorder: a review. Addict Behav. 2005;30:1824–1833. | Conducted exclusively in high-risk populations
Cornelius, Jack R., Clark, Duncan B., Bukstein, Oscar G., Kelly, Thomas M., Salloum, Ihsan M., and Wood, D. Scott. Fluoxetine in adolescents with comorbid major depression and an alcohol use disorder: A 3-year follow-up study. Addictive Behaviors 2005;30(4), 807–814. | Conducted exclusively in high-risk populations
Council of Scientific Affairs (A-05). Safety and Efficacy of Selective Serotonin Reuptake Inhibitors (SSRIs) in Children and Adolescents. 10. 2006. | Does not meet criteria for study design
Courtney DB. Selective serotonin reuptake inhibitor and venlafaxine use in children and adolescents with major depressive disorder: a systematic review of published randomized controlled trials. Can J Psychiatry. 2004;49:557–563. | Used as source document only
Creed F. Does psychological treatment help only those patients with severe irritable bowel syndrome who also have a concurrent psychiatric disorder? The Australian and New Zealand journal of psychiatry. 2005;807–815. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Crisp, Heather L., Gudmundsen, Gretchen R., and Shirk, Stephen R. Transporting Evidence-Based Therapy for Adolescent Depression to the School Setting. Education & Treatment of Children 2006;29(2), 287–309. | Does not meet criteria for study design
Cuijpers P, van Straten A, Smit F. Preventing the incidence of new cases of mental disorders: a meta-analytic review. J Nerv Ment Dis. 2005;193:119–125. | Does not focus on depression screening or treatment or harms of either
Cuijpers P, van Straten A, Smits N, Smit F. Screening and early psychological intervention for depression in schools : Systematic review and meta-analysis. Eur Child Adolesc Psychiatry. 2006;15(5):300–7. | Used as source document only
Cuijpers P, Van SA, Warmerdam L. Problem solving therapies for depression: a meta-analysis. European Psychiatry: the Journal of the Association of European Psychiatrists. 2007;22:9–15. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Curry JF, Wells KC. Striving for Effectiveness in the Treatment of Adolescent Depression: Cognitive Behavior Therapy for Multisite Community Intervention. Cognitive and Behavioral Practice. 2005;12:-185. | Does not meet criteria for study design
Curtis, SE. Cognitive-behavioural treatment of adolescent depression. Unpublished doctoral dissertation. 1992. Logan, Utah State University. | Does not meet quality criteria: high potential for bias due to author-conducted interventions and outcome testing
Dana, Edward Carleton. A cognitive-behavioral intervention for conduct-disordered and concurrently conduct-disorded and depressed children. Dissertation Abstracts International Section A: Humanities and Social Sciences 59(1-A), 0322. 1998. | Conducted exclusively in high-risk populations
den Boer PCAM, Wiersma D, Russo S, van den Bosch RJ. Paraprofessionals for anxiety and depressive disorders. Cochrane Database of Systematic Reviews. 2006. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
De Cuyper S, Timbremont B, Braet C, De B, V, Wullaert T. Treating depressive symptoms in schoolchildren: a pilot study. European Child & Adolescent Psychiatry 2004;13(2):105–14. | Focus on patients with minor depression or dysthymia or doesn't present MDD outcomes separately
de Jonghe F. Combining psychotherapy and antidepressants in the treatment of depression. Journal of Affective Disorders. 2001;217–229. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Deas D. A double-blind, placebo-controlled trial of sertraline in depressed adolescent alcoholics: A pilot study. Human psychopharmacology. 2000;461–469. | Conducted exclusively in high-risk populations
den Boer PCAM, Wiersma D, Russo S, van den Bosch RJ. Paraprofessionals for anxiety and depressive disorders. Cochrane Database of Systematic Reviews. 2006. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Denton WH, Walsh SR, Daniel SS. Evidence-based practice in family therapy: adolescent depression as an example. J Marital Fam Ther. 2002;28:39–45. | Does not meet criteria for study design
Diamond G, Josephson A. Family-based treatment research: a 10-year update. J Am Acad Child Adolesc Psychiatry. 2005;44:872–887. | Does not meet criteria for study design
Doggrell SA. Fluoxetine—do the benefits outweigh the risks in adolescent major depression?. Expert Opinion on Pharmacotherapy. 2005;6:147–150. | Does not meet criteria for study design
Donaldson D. Treatment for adolescents following a suicide attempt: results of a pilot trial. J Am Acad Child Adolesc Psychiatry. 2005;113–120. | Does not focus on depression screening or treatment or harms of either
Duff AJ. Psychological interventions in cystic fibrosis and asthma. Paediatric Respiratory Reviews 2001;2(4):350–7. | Does not focus on depression screening or treatment or harms of either
Eggert LL, Thompson EA, Herting JR, Nicholas LJ. Reducing suicide potential among high-risk youth: tests of a school-based prevention program. Suicide Life Threat Behav. 1995;25:276–296. | Focus on screening for suicide risk
Emslie GJ, Heiligenstein JH, Hoog SL et al. Fluoxetine treatment for prevention of relapse of depression in children and adolescents: a double-blind, placebo-controlled study. Journal of the American Academy of Child & Adolescent Psychiatry 2004;43(11):1397–405. | Focus on prevention of depression (either universal or among populations with risk factors)
Emslie GJ, Hughes CW, Crismon ML et al. A feasibility study of the childhood depression medication algorithm: the Texas Children's Medication Algorithm Project (CMAP). Journal of the American Academy of Child & Adolescent Psychiatry 2004;43(5):519–27. | Does not focus on depression screening or treatment or harms of either
Emslie GJ, Rush AJ, Weinberg WA, Kowatch RA, Carmody T, Mayes TL. Fluoxetine in child and adolescent depression: acute and maintenance treatment. Depress Anxiety. 1998;7:32–39. | Does not meet criteria for study design
Emslie GJ, Ryan ND, Wagner KD. Major depressive disorder in children and adolescents: clinical trial design and antidepressant efficacy. J Clin Psychiatry. 2005;66 Suppl 7:14–20. | Does not meet criteria for study design
Ettelson, Rebecca Gail. The treatment of adolescent depression. Dissertation Abstracts International: Section B: The Sciences and Engineering 2003;64(4-B), 1899. | Focus on patients with minor depression or dysthymia or doesn't present MDD outcomes separately
Fawcett J, Barkin RL. A meta-analysis of eight randomized, double-blind, controlled clinical trials of mirtazapine for the treatment of patients with major depression and symptoms of anxiety. J Clin Psychiatry. 1998;59:123–127. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Fischer, SA. Development and evaluation of group cognitive-behavioral therapy for depressed and suicidal adolescents in juvenile detention. Unpublished doctoral dissertation. 1995. Tuscaloosa, University of Alabama. | Does not meet setting criteria
Fletcher, Janine, Lovell, Karina, Bower, Peter, Campbell, Malcolm, and Dickens, Chris. Process and Outcome of a Non-Guided Self-Help Manual for Anxiety and Depression in Primary Care: A Pilot Study. Behavioural and Cognitive Psychotherapy 2005;33(3), 319–331. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Gaynor, Scott T. Complementing cbt with learning through in vivo experience (live): An open clinic trial with depressed adolescents. Dissertation Abstracts International: Section B: The Sciences and Engineering 2001;61(7-B), 3842. | Does not meet criteria for study design
Geddes J, Butler R. Depressive disorders. Clin Evid. 2002;951–973. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Glass RM. Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents with Depression Study (TADS) randomized controlled trial. The Journal of pediatrics. 2005; 146(1):145. | Does not meet criteria for study design
Glod CA LA. Bupropion Versus Citalopram Versus Placebo in Adolescents With Major Depression. 157th Annual Meeting of the American Psychiatric Association. 2004;2004–2006. | Does not meet criteria for study design
Goodyer I, Dubicka B, Wilkinson P et al. Selective serotonin reuptake inhibitors (SSRIs) and routine specialist care with and without cognitive behaviour therapy in adolescents with major depression: randomised controlled trial. BMJ. 2007; 335(7611):142 | Focus on treatment comparison, matching, or fine-tuning
Green, H., McGinnity, A., Meltzer, H., Ford, T., and Goodman, R. Mental health of children and young people in Great Britain, 2004. 1–284. 2005. Hampshire, Palgrave Macmillan. | Does not focus on depression screening or treatment or harms of either
Green J. Depressing research. Lancet. 2004;363:2088. | Does not meet criteria for study design
Hammerness PG, Vivas FM, Geller DA. Selective serotonin reuptake inhibitors in pediatric psychopharmacology: a review of the evidence. J Pediatr. 2006;148:158–165. | Does not meet criteria for study design
Hamrin V, Pachler MC. Depression in children and adolescents: the latest evidence-based psychopharmacological treatments. J Psychosoc Nurs Ment Health Serv. 2004;42:10–15. | Does not meet criteria for study design
Hansen RA, Gartlehner G, Lohr KN, Gaynes BN, Carey TS. Efficacy and safety of second-generation antidepressants in the treatment of major depressive disorder. Ann Intern Med. 2005;143(6):415–426. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Harrington R, Whittaker J, Shoebridge P, Campbell F. Systematic review of efficacy of cognitive behaviour therapies in childhood and adolescent depressive disorder. BMJ. 1998;316:1559–1563. | Used as source document only
Harrington R, Wood A, Verduyn C. Clinically depressed adolescents. Graham, Philip Jeremy (Ed). 1998;NY, US. | Focus on treatment comparison, matching, or fine-tuning
Harrington R. Randomized trial of a home-based family intervention for children who have deliberately poisoned themselves. J Am Acad Child Adolesc Psychiatry. 1998;512–518. | Population not comparable to primary care
Harrington R. Deliberate self-poisoning in adolescence: why does a brief family intervention work in some cases and not others? Journal of Adolescence. 2000;13–20. | Population not comparable to primary care
Hayes, Claire and Morgan, Mark. Evaluation of a Psychoeducational Program to Help Adolescents Cope. Journal of Youth and Adolescence 2005;34(2), 111–121. | Does not focus on depression screening or treatment or harms of either
Hazell P, O'Connell D, Heathcote D, Robertson J, Henry D. Efficacy of tricyclic drugs in treating child and adolescent depression: a meta-analysis. BMJ. 1995;310:897–901. | Focus on efficacy of Tricyclic anti-depressants, atypical anti-depressants, MAOI inhibitors, or other medications/procedures that are not primary care feasible or referable
Hazell P. Depression in Children and Adolescents. Clinical Evidence. 2002;307–313. | Does not meet criteria for study design
Hazell P. Depression in children and adolescents. Evid Based Ment Health. 2003;6:103–104. | Does not meet criteria for study design
Hegmann T. The case of the missing evidence: antidepressant use in children. JAAPA. 2004;17:15–16. | Does not meet criteria for study design
Helping depressed children. Nature. 2004;431:111. | Does not meet criteria for study design
Hickman, KA. Effects of social skills training on depressed children attending a behavioral day treatment program. Unpublished doctoral dissertation. 1994. Hempstead, New York, Hofstra University. | Population not comparable to primary care
Hodgkinson, B., Evans, D., O'Donnell, A., and Walsh, K. Comparing the effectiveness of individual therapy and group therapy in the treatment of depression: systematic review. Adelaide, S. Australia, Australia: Joanna Briggs Institute for Evidence Based Nursing and Midwifery. 1999. | Precedes search period
Hollon, Steven D., Garber, Judy, and Shelton, Richard C. Treatment of Depression in Adolescents With Cognitive Behavior Therapy and Medications: A Commentary on the TADS Project. Cognitive and Behavioral Practice 2005;12(2), 149–155. | Does not meet criteria for study design
Hughes CW, Emslie GJ, Crismon ML et al. Texas Children's Medication Algorithm Project: update from Texas Consensus Conference Panel on Medication Treatment of Childhood Major Depressive Disorder. J Am Acad Child Adolesc Psychiatry. 2007;2007:667–686. | Does not meet criteria for study design
Hyun MS, Chung HI, Lee YJ. The effect of cognitive-behavioral group therapy on the self-esteem, depression, and self-efficacy of runaway adolescents in a shelter in South Korea. Applied nursing research : ANR. 2005;160–166. | Does not meet population criteria
James A. The use of Selective Serotonin Re-uptake Inhibitors (SSRIs) in the treatment of depressive disorders in children and adolescents. Epidemiol Psichiatr Soc. 2005;14:63–67. | Does not meet criteria for study design
Jane-Llopis E, Hosman C, Jenkins R, Anderson P. Predictors of efficacy in depression prevention programmes. Meta-analysis. Br J Psychiatry. 2003;183:384–397. | Focus on prevention of depression (either universal or among populations with risk factors)
Jaycox LH, Reivich KJ, Gillham J, Seligman ME. Prevention of depressive symptoms in school children. Behav Res Ther. 1994;32:801–816. | Focus on prevention of depression (either universal or among populations with risk factors)
Jensen PS. After TADS, can we measure up, catch up, and ante up? Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:1456–1460. | Does not meet criteria for study design
Jensen, Peter S. NIMH's TADS: More Than Just a Tad of Progress? Cognitive and Behavioral Practice 2005;12(2), 156–158. | Does not meet criteria for study design
Jorm AF, Allen NB, O'Donnell CP, Parslow RA, Purcell R, Morgan AJ. Effectiveness of complementary and self-help treatments for depression in children and adolescents. Med J Aust. 2006;185:368–372. | Does not meet criteria for study design
Jureidini JN, Doecke CJ, Mansfield PR, Haby MM, Menkes DB, Tonkin A L. Efficacy and safety of antidepressants for children and adolescents. BMJ. 2004;328:879–883. | Does not meet criteria for study design
Kahn, RHC. The effect of a group support intervention program on depression, social adjustment and self-esteem. Unpublished doctoral dissertation. 1989. Washington, DC, Catholic University of America. | Focus on patients with minor depression or dysthymia or doesn't present MDD outcomes separately
Kaltenthaler E, Shackley P, Stevens K, Beverley C, Parry G, Chilcott J. A systematic review and economic evaluation of computerised cognitive behaviour therapy for depression and anxiety. Health Technol Assess. 2002;6:1–89. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Kaufman, Noah K., Rohde, Paul, Seeley, John R., Clarke, Gregory N., and Stice, Eric. Potential Mediators of Cognitive-Behavioral Therapy for Adolescents With Comorbid Major Depression and Conduct Disorder. Journal of Consulting and Clinical Psychology 2005;73(1), 38–46. | Conducted exclusively in high-risk populations
Kazdin AE, Bass D, Ayers WA, Rodgers A. Empirical and clinical focus of child and adolescent psychotherapy research. J Consult Clin Psychol. 1990;58:729–740. | Does not meet criteria for study design
Kennard, Betsy D., Ginsburg, Golda S., Feeny, Norah C., Sweeney, Michael, and Zagurski, Robin. Implementation Challenges to TADS Cognitive-Behavioral Therapy. Cognitive and Behavioral Practice 2005;12(2), 230–239. | Does not focus on depression screening or treatment or harms of either
Kerfoot, Michael, Harrington, Richard, Harrington, Val, Rogers, Julia, and Verduyn, Chrissie. A step too far? Randomized trial of cognitive-behaviour therapy delivered by social workers to depressed adolescents. European Child & Adolescent Psychiatry 2004;13(2), 92–99. | Focus on patients with minor depression or dysthymia or doesn't present MDD outcomes separately
King CA, Kirschenbaum DS. An experimental evaluation of a school-based program for children at risk: Wisconsin Early Intervention. J Community Psychol. 1990;18:-177. | Does not focus on depression screening or treatment or harms of either
Klein DN, Dougherty LR, Olino TM. Toward guidelines for evidence-based assessment of depression in children and adolescents. J Clin Child Adolesc Psychol. 2005;34:412–432. | Does not meet criteria for study design
Kolko DJ, Brent DA. Cognitive and family therapies for adolescent depression: treatment specificity, mediation, and moderation. J Consult Clin Psychol. 2000;603–614. | Focus on treatment comparison, matching, or fine-tuning
Kowalenko, Nick, Rapee, Ronald M., Simmons, Julie, Wignall, Ann, Hoge, Rebecca, Whitefield, Kathy, Starling, Julia, Stonehouse, Roger, and Baillie, Andrew J. Short-term effectiveness of a school-based early intervention program for adolescent depression. Clinical Child Psychology and Psychiatry 2005;10, 493–507. | Does not meet quality criteria: important aspects of study design not reported (e.g., adherence, fidelity), assignment not random at one school
Kratochvil, Christopher J., Simons, Anne, Vitiello, Benedetto, Walkup, John, Emslie, Graham, Rosenberg, David, and March, John S. A Multisite Psychotherapy and Medication Trial for Depressed Adolescents: Background and Benefits. Cognitive and Behavioral Practice 2005;12(2), 159–165. | Does not meet criteria for study design
Lamb JM, Puskar KR, Sereika SM, Corcoran M. School-based intervention to promote coping in rural teens. MCN Am J Matern Child Nurs. 1998;23:187–194. | Focus on prevention of depression (either universal or among populations with risk factors)
Lerner M. Treatment of Suicide Ideators: A Problem Solving Approach. Behavior Therapy. 1990;21:403–411. | Focus on screening for suicide risk
Lewinsohn PM, Clarke GN. Psychosocial treatments for adolescent depression. Clin Psychol Rev. 1999;19:329–342. | Does not meet criteria for study design
Liddle B, Spence SH. Cognitive-behaviour therapy with depressed primary school children: A cautionary note. Behavioural Psychotherapy. 1990;18:85–102. | Does not meet quality criteria: important aspects of study design not reported (e.g., adherence, attrition, fidelity, handling of missing data)
Lima MS, Hotopf M. Pharmacotherapy for dysthymia. Cochrane Database of Systematic Reviews. 2006. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Lima MS, Moncrieff J, Soares BGO. Drugs versus placebo for dysthymia. Cochrane Database of Systematic Reviews. 2006. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Lip GYH, Lane DA, Millane TA. Psychological interventions for depression in adolescent and adult congenital heart disease. Cochrane Database of Systematic Reviews. 2006. | Focus on patients with severe medical illnesses (e.g., cancer)
Listug-Lunde, Lori B. A cognitive-behavioral treatment for depression in Native American middle-school students. Dissertation Abstracts International: Section B: The Sciences and Engineering 2005;66(2-B), 1176. | Does not meet quality criteria: outcome assessment not blinded, 70% of control group received treatment
Lynch FL, Hornbrook M, Clarke GN et al. Cost-effectiveness of an intervention to prevent depression in at-risk teens. Arch Gen Psychiatry. 2005;62:1241–1248. | Focus on prevention of depression (either universal or among populations with risk factors)
MacGillivray S, Arroll B, Hatcher S et al. Efficacy and tolerability of selective serotonin reuptake inhibitors compared with tricyclic antidepressants in depression treated in primary care: systematic review and meta-analysis. BMJ. 2003;326:1014–1017. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Mandoki MW, Tapia MR, Tapia MA, Sumner GS, Parker JL. Venlafaxine in the treatment of children and adolescents with major depression. Psychopharmacol Bull. 1997;33:149–154. | Focus on efficacy of Tricyclic anti-depressants, atypical anti-depressants, MAOI inhibitors, or other medications/procedures that are not primary care feasible or referable
Mann JJ, Emslie G, Baldessarini RJ et al. ACNP Task Force report on SSRIs and suicidal behavior in youth. Neuropsychopharmacology. 2006;31:473–492. | Used as source document only
March JS, Klee BJ, Kremer CM. Treatment benefit and the risk of suicidality in multicenter, randomized, controlled trials of sertraline in children and adolescents. J Child Adolesc Psychopharmacol. 2006;16:91–102. | Used as source document only
March JS. Authors of TADS study reply to letter raising concerns. Br Med J. 2005; 330(7493):730–1. | Does not meet criteria for study design
March JS. Treatment for adolescents with depression study (Tads). 158th Annual Meeting of the American Psychiatric Association. 2005;2005–2026. | Does not meet criteria for study design
March, John S. Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial: Reply. JAMA: Journal of the American Medical Association 2004;292(21), 2578–2579. | Does not meet criteria for study design
Marks IM. The maturing of therapy. Some brief psychotherapies help anxiety/depressive disorders but mechanisms of action are unclear. British Journal of Psychiatry. 2002;180:200–204. | Does not meet criteria for study design
McClellan JM, Werry JS. Evidence-based treatments in child and adolescent psychiatry: an inventory. J Am Acad Child Adolesc Psychiatry. 2003;42:1388–1400. | Does not report outcomes listed in inclusion criteria
Medicines and Healthcare Products Regulatory Agency. Selective Serotonin reuptake inhibitors (SSRIs): overview of regulatory status and CSM advice relating to major depressive disorder (MDD) in children and adolescents - summary of clinical trials. 1–190. 2003. | Used as source document only
Melvin GA, Tonge BJ, King NJ, Heyne D, Gordon MS, Klimkeit E. A comparison of cognitive-behavioral therapy, sertraline, and their combination for adolescent depression. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:1151–1161. | Focus on treatment comparison, matching, or fine-tuning
Merry S, McDowell H, Hetrick S, Bir J, Muller N. Psychological and/or educational interventions for the prevention of depression in children and adolescents. Cochrane Database Syst Rev. 2004;CD003380. | Focus on prevention of depression (either universal or among populations with risk factors)
Merry S, McDowell H, Wild CJ, Bir J, Cunliffe R. A randomized placebo-controlled trial of a school-based depression prevention program. Journal of the American Academy of Child & Adolescent Psychiatry 2004;43(5):538–47. | Focus on prevention of depression (either universal or among populations with risk factors)
Michael KD, Crowley SL. How effective are treatments for child and adolescent depression? A meta-analytic review. Clin Psychol Rev. 2002;22:247–269. | Precedes search period
Michael KD, Huelsman TJ, Crowley SL. Interventions for Child and Adolescent Depression: Do Professional Therapists Produce Better Results? Journal of Child and Family Studies. 2005;14:11855,4–1185570. | Precedes search period
Moak DH. Sertraline and cognitive behavioral therapy for depressed alcoholics: results of a placebo-controlled trial. Journal of Clinical Psychopharmacology. 2003;553–562. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Moldenhauer Z, Melnyk BM. Use of antidepressants in the treatment of child and adolescent depression: are they effective? Pediatr Nurs. 1999;25:643–646. | Precedes search period
Moldenhauer, Zendi. Adolescent depression: A primary care pilot intervention study. Dissertation Abstracts International: Section B: The Sciences and Engineering 2004;65(2-B), 656. | Does not meet quality criteria: outcome assessment not blinded, high level of attention received by control group, differences between accepters and decliners
Moor S, Ann M, Hester M et al. Improving the recognition of depression in adolescence: Can we teach the teachers? J Adolesc. 2007; 30(1):81–95. | Does not focus on depression screening or treatment or harms of either
Moore M, Carr A. Depression and grief. Carr, Alan (Ed). 2000;364. | Conducted exclusively in high-risk populations
Moreno C, Arango C, Parellada M, Shaffer D, Bird H. Antidepressants in child and adolescent depression: where are the bugs? Acta Psychiatr Scand. 2007;115:184–195. | Does not meet criteria for study design
Moscovitch A. A placebo-controlled study of sertraline in the treatment of outpatients with seasonal affective disorder. Psychopharmacology (Berl). 2004;390–397. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Mufson L, Moreau D, Weissman MM, Wickramaratne P, Martin J, Samoilov A. Modification of interpersonal psychotherapy with depressed adolescents (IPT-A): phase I and II studies. J Am Acad Child Adolesc Psychiatry. 1994;1994:695–705. | Does not meet criteria for study design
Mufson, L. and Dorta, K. P. Interpersonal psychotherapy for depressed adolescents: Theory, practice, and research. 2000. | Does not meet criteria for study design
Mufson, Laura and Moreau, Donna. Interpersonal psychotherapy for adolescent depression. 35–66. 1998. Washington, DC, American Psychiatric Association. | Does not focus on depression screening or treatment or harms of either
Mulrow CD, Williams JW, Jr., Trivedi M et al. Treatment of depression—newer pharmacotherapies. Psychopharmacol Bull. 1998;34:409–795. | Precedes search period
National Institute for Clinical Excellence. Depression in Children and Young People: Identification and management in primary, community and secondary care. 1–233. 2005. Northhamptonshire, The British Psychological Society. | Used as a source document only
Nelms BC. Childhood depression: Be on the alert. Journal of Pediatric Health Care 2003;17(4):161–2. | Does not meet criteria for study design
Newcorn JH. Selective serotonin reuptake inhibitor treatment of major depressive disorder in children and adolescents.(comment). Current Psychiatry Reports. 2004;6:85–87. | Does not meet criteria for study design
O'Kearney, Richard, Gibson, Mal, Christensen, Helen, and Griffiths, Kathy M. Effects of a cognitive-behavioural internet program on depression, vulnerability to depression and stigma in adolescent males: A school-based controlled trial. Cognitive Behaviour Therapy 2006;35(1), 43–54. | Focus on prevention of depression (either universal or among populations with risk factors)
Oldham J. The risk/benefit ratio of psychiatric treatment. Journal of Psychiatric Practice. 2005;11:137. | Does not meet criteria for study design
Olfson M, Marcus SC, Shaffer D. Antidepressant drug therapy and suicide in severely depressed children and adults: A case-control study. Arch Gen Psychiatry. 2006;63:865–872. | Does not report outcomes listed in inclusion criteria
Papanikolaou K, Richardson C, Pehlivanidis A, Papadopoulou-Daifoti Z. Efficacy of antidepressants in child and adolescent depression: a meta-analytic study. J Neural Transm. 2006;113:399–415. | Used as source document only
Patterson GR, DeGarmo D, Forgatch MS. Systematic changes in families following prevention trials. J Abnorm Child Psychol. 2004;32:621–633. | Does not focus on depression screening or treatment or harms of either
Pattison, Sue and Harris, Belinda. Counselling children and young people: A review of the evidence for its effectiveness. Counselling & Psychotherapy Research 2006; 6(4), 233–237. | Used as source document only
Pignone, M. P., Gaynes, B. N., Rushton, J. L., Mulrow, C. D., Orleans, C. T., Whitener, B. L., Mills, C., and Lohr, K. N. Screening for Depression. i-D-83. 2002. Rockville, MD, Agency for Healthcare Research and Quality. | Used as source document only
Pine DS, Cohen JA. Trauma in children and adolescents: risk and treatment of psychiatric sequelae. (Review) (80 refs). Biological Psychiatry. 2002;51:519–531. | Does not meet criteria for study design
Pruitt, Irene T. P. Family Treatment Approaches for Depression in Adolescent Males. American Journal of Family Therapy 2007;35(1), 69–81. | Does not meet criteria for study design
Puskar K. Effect of the Teaching Kids to Cope (TKC) program on outcomes of depression and coping among rural adolescents. Journal of child and adolescent psychiatric nursing : official publication of the Association of Child and Adolescent Psychiatric Nurses, Inc. 2003;71–80. | Does not meet quality criteria: no clear description of intervention and control groups, important aspects of study design not reported (e.g., patient characteristics)
Quintana H, Butterbaugh GJ, Purnell W, Layman AK. Fluoxetine monotherapy in attention-deficit/hyperactivity disorder and comorbid non-bipolar mood disorders in children and adolescents. Child Psychiatry & Human Development. 2007;37:241–253. | Conducted exclusively in high-risk populations
Rapaport MH. Prevalence, recognition, and treatment of comorbid depression and anxiety. J Clin Psychiatry. 2001;62:Suppl-10. | Does not meet criteria for study design
Rawson HE, Tabb LC. Effects of therapeutic intervention on childhood depression. Child & Adolescent Social Work Journal. 1993;10:39–52. | Population not comparable to primary care
Reed MK. Social skills training to reduce depression in adolescents. Adolescence. 1994;29:293–302. | Does not meet quality criteria: outcome assessment not blinded, lack of usable data, important aspects of study design not reported (e.g., method of assessment for MDD)
Reger G, Wong-McDonald A, Liberman RP. Psychiatric rehabilitation in a community mental health center. Psychiatr Serv. 2003;54:1457–1459. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Reinecke MA, Ryan NE, DuBois DL. Cognitive-behavioral therapy of depression and depressive symptoms during adolescence: a review and meta-analysis. J Am Acad Child Adolesc Psychiatry. 1998;37:26–34. | Used as source document only
Reynolds WM, Coats KI. A comparison of cognitive-behavioral therapy and relaxation training for the treatment of depression in adolescents. J Consult Clin Psychol. 1986;54:653–660. | Does not meet quality criteria: outcome assessment not blinded, differential attrition, both interventions conducted by same therapist
Richards A. PHASE: a randomised, controlled trial of supervised self-help cognitive behavioural therapy in primary care. The British journal of general practice : the journal of the Royal College of General Practitioners. 2003;764–770. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Riggs, Paula D. and Davies, Robert D. A clinical approach to integrating treatment for adolescent depression and substance abuse. Journal of the American Academy of Child & Adolescent Psychiatry 2002;41(10), 1253–1255. | Conducted exclusively in high-risk populations
Rihmer Z, Akiskal H. Do antidepressants t(h)reat(en) depressives? Toward a clinically judicious formulation of the antidepressant-suicidality FDA advisory in light of declining national suicide statistics from many countries. Journal of Affective Disorders. 2006;94:3–13. | Does not meet criteria for study design
Rishel CW, Greeno CG, Marcus SC et al. Impact of maternal mental health status on child mental health treatment outcome. Community Mental Health Journal 2006;42(1):1–12. | Conducted exclusively in high-risk populations
Rohde P, Clarke GN, Mace DE, Jorgensen JS, Seeley JR. An efficacy/effectiveness study of cognitive-behavioral treatment for adolescents with comorbid major depression and conduct disorder. Journal of the American Academy of Child & Adolescent Psychiatry 2004;43(6):660–8. | Conducted exclusively in high-risk populations
Rohde P. Impact of comorbidity on a cognitive-behavioral group treatment for adolescent depression. J Am Acad Child Adolesc Psychiatry. 2001;795–802. | Conducted exclusively in high-risk populations
Rollman BL, Hanusa BH, Gilbert T, Lowe HJ, Kapoor WN, Schulberg HC. The electronic medical record. A randomized trial of its impact on primary care physicians' initial management of major depression (corrected). Arch Intern Med. 2001;161:189–197. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Ryan ND. Medication treatment for depression in children and adolescents. Cns Spectrums 2003;8(4):283–7. | Does not meet criteria for study design
Ryan ND. Treatment of depression in children and adolescents. Lancet. 2005;366:933–940. | Does not meet criteria for study design
Rynn M, Wagner KD, Donnelly C et al. Long-term sertraline treatment of children and adolescents with major depressive disorder. Journal of Child & Adolescent Psychopharmacology 2006;16(1–2):103–16. | Does not meet criteria for study design
Safer DJ. Should selective serotonin reuptake inhibitors be prescribed for children with major depressive and anxiety disorders? Pediatrics. 2006;118:1248–1251. | Does not meet criteria for study design
Salerian AJ. Use of selective serotonin reuptake inhibitors in childhood depression. Lancet. 2004;364:660–661. | Does not meet criteria for study design
Salkovskis P, Rimes K, Stephenson D, Sacks G, Scott J. A randomized controlled trial of the use of self-help materials in addition to standard general practice treatment of depression compared to standard treatment alone. Psychological Medicine 2006;36(3):325–33. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Sanford, Mark, Boyle, Michael, McCleary, Lynn, Miller, Jennifer, Steele, Margaret, Duku, Eric, and Offord, David. A pilot study of adjunctive family psychoeducation in adolescent major depression: Feasibility and treatment effect. Journal of the American Academy of Child & Adolescent Psychiatry 2006;45(4), 386–395. | Focus on treatment comparison, matching, or fine-tuning
Sanford, Mark, Byrne, Carolyn, Williams, Susan, Atley, Sandy, Ridley, Ted, Miller, Jennifer, and Allin, Heather. A Pilot Study of a Parent-Education Group for Families Affected by Depression. Canadian Journal of Psychiatry 2003;48(2), 78–86. | Conducted exclusively in high-risk populations
Santor DA, Kusumakar V. Open trial of interpersonal therapy in adolescents with moderate to severe major depression: effectiveness of novice IPT therapists. Journal of the American Academy of Child & Adolescent Psychiatry 2001;40(2):236–40. | Does not meet criteria for study design
Scahill L, Hamrin V, Pachler ME. The use of selective serotonin reuptake inhibitors in children and adolescents with major depression. Journal of Child & Adolescent Psychiatric Nursing. 2005;18:86–89. | Does not meet criteria for study design
Scahill L. Selective serotonin reuptake inhibitors in children and adolescents with major depression. Revista Brasileira de Psiquiatria. 2005;27:91–92. | Does not meet criteria for study design
Schmitz JM AP. Fluoxetine treatment of cocaine-dependent patients with major depressive disorder. Drug Alcohol Depend. 2001;207–214. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Scott, Cynthia V. Evaluation of cognitive-behavioral group therapy in treating depressive symptoms in prepubertal children: A pilot study. Dissertation Abstracts International: Section B: The Sciences and Engineering 1999;60(6-B), 2960. | Does not meet quality criteria: outcome assessment not blinded, important aspects of study design not reported (e.g., attrition, number of subjects within groups)
Sharp SC, Hellings JA. Efficacy and safety of selective serotonin reuptake inhibitors in the treatment of depression in children and adolescents: practitioner review. Clinical Drug Investigation. 2006;26:247–255. | Used as source document only
Sheffield J. A universally administered primary prevention programme for depression reduces symptoms in German adolescents with low self-efficacy. Evid Based Ment Health. 2006;9:51. | Focus on prevention of depression (either universal or among populations with risk factors)
Simeon JG, Dinicola VF, Ferguson HB, Copping W. Adolescent depression: a placebo-controlled fluoxetine treatment study and follow-up. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14:791–795. | Does not meet quality criteria: important aspects of study design not reported (e.g., attrition, blinding of outcome assessment), lack of usable data
Soffer AG. School-based social skills training to reduce children's depressive symptomatology. Dissertation Abstracts International 2003;63(12-A):4224. | Focus on prevention of depression (either universal or among populations with risk factors)
Solhkhah R, Wilens TE, Daly J, Prince JB, Van Patten SL, Biederman J. Bupropion SR for the treatment of substance-abusing outpatient adolescents with attention-deficit/hyperactivity disorder and mood disorders. Journal of Child & Adolescent Psychopharmacology 2005;15(5):777–86. | Conducted exclusively in high-risk populations
Stark KD. Childhood depression: School-based intervention. New York: Guilford Press; 1990. | Focus on treatment comparison, matching, or fine-tuning
Stein BD, Jaycox LH, Kataoka SH et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial.(see comment). JAMA 2003;290(5):603–11. | Conducted exclusively in high-risk populations
Stein MD, Zitner LE, Jensen PS. Adherence to treatment of depression in active injection drug users: the minerva study. J Subst Abuse Treat. 2004;87–93. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Stein RE, Zitner LE, Jensen PS. Interventions for adolescent depression in primary care. Pediatrics. 2006;118:669–682. | Used as source document only
Steiner M, Hirschberg AL, Bergeron R, Holland F, Gee MD, Van EE. Luteal phase dosing with paroxetine controlled release (CR) in the treatment of premenstrual dysphoric disorder. American Journal of Obstetrics & Gynecology. 2005;193:352–360. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Sweeney, Michael, Robins, Michele, Ruberu, Maryse, and Jones, Jennifer. African-American and Latino Families in TADS: Recruitment and Treatment Considerations. Cognitive and Behavioral Practice 2005;12(2), 221–229. | Does not meet criteria for study design
Szigethy, Eva, Carpenter, Johanna, Baum, Emily, Kenney, Elyse, Baptista-Neto, Lourival, Beardslee, William R., and DeMaso, David Ray. Case study: Longitudinal treatment of adolescents with depression and inflammatory bowel disease. Journal of the American Academy of Child & Adolescent Psychiatry 2006;45(4), 396–400. | Does not meet criteria for study design
Talbot, Nancy L., Conwell, Yeates, O'Hara, Michael W., Stuart, Scott, Ward, Erin A., Gamble, Stephanie A., Watts, Arthur, and Tu, Xin. Interpersonal psychotherapy for depressed women with sexual abuse histories: A pilot study in a community mental health center. Journal of Nervous and Mental Disease 2005;193(12), 847–850. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Thaper, Anita. Texas Medication Algorithm Project Overview. Texas. 2006. | Excluded for study relevance
Tucker P, Beebe KL, Burgin C et al. Paroxetine treatment of depression with posttraumatic stress disorder: effects on autonomic reactivity and cortisol secretion. Journal of Clinical Psychopharmacology. 2004;24:131–140. | Does not meet population criteria
Valuck RJ, Libby AM, Sills MR, Giese AA, Allen RR. Antidepressant treatment and risk of suicide attempt by adolescents with major depressive disorder: a propensity-adjusted retrospective cohort study. CNS Drugs. 2004;18:1119–1132. | Does not report outcomes listed in inclusion criteria
Vergouwen AC BA. A cluster randomized trial comparing two interventions to improve treatment of major depression in primary care. Psychol Med. 2005;25–33. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Vitiello B. Selective serotonin reuptake inhibitors (SSRIs) in children and adolescents. Journal of Child & Adolescent Psychopharmacology. 2006;16:7–9. | Does not meet criteria for study design
von Knorring, Anne Liis, Olsson, Gunilla Ingrid, Thomsen, Per Hove, Lemming, Ole Michael, and Hulten, Agnes. A randomized, double-blind, placebo-controlled study of citalopram in adolescents with major depressive disorder. Journal of Clinical Psychopharmacology 2006;26(3), 311–315. | Does not meet quality criteria: control group conditions not clearly described, eligibility criteria changed midway through study, important aspects of study design not reported (blinding of outcome assessment)
Vostanis P, Feehan C, Grattan E, Bickerton WL. A randomised controlled out-patient trial of cognitive-behavioural treatment for children and adolescents with depression: 9-month follow-up. J Affect Disord. 1996;40:105–116. | Focus on treatment comparison, matching, or fine-tuning
Vostanis P, Feehan C, Grattan E, Bickerton WL. Treatment for children and adolescents with depression: Lessons from a controlled trial. Clinical Child Psychology and Psychiatry. 1996;1:199–212. | Focus on treatment comparison, matching, or fine-tuning
Walker EA, Katon WJ, Russo. Predictors of outcome in a primary care depression trial. Journal of general internal medicine : official journal of the Society for Research and Education in Primary Care Internal Medicine. 2000;859–867. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Wallace AE, Neily J, Weeks WB, Friedman MJ. A cumulative meta-analysis of selective serotonin reuptake inhibitors in pediatric depression: Did unpublished studies influence the efficacy/safety debate? (References). Journal of Child and Adolescent Psychopharmacology. 2006;16:-58. | Used as source document only
Weersing, V. Robin, Iyengar, Satish, Kolko, David J., Birmaher, Boris, and Brent, David A. Effectiveness of Cognitive-Behavioral Therapy for Adolescent Depression: A Benchmarking Investigation. Behavior Therapy 2006;37(1), 36–48. | Does not meet criteria for study design
Weersing VR, Weisz JR. Community clinic treatment of depressed youth: benchmarking usual care against CBT clinical trials. Journal of Consulting & Clinical Psychology. 2002;70:299–310. | Does not meet criteria for study design
Weissman MM. Recent non-medication trials of interpersonal psychotherapy for depression. International Journal of Neuropsychopharmacology. 2007;10:117–122. | Does not meet criteria for study design
Weisz JR, Thurber CA, Sweeney L, Proffitt VD, LeGagnoux GL. Brief treatment of mild-to-moderate child depression using primary and secondary control enhancement training. J Consult Clin Psychol. 1997;65:703–707. | Does not meet quality criteria: no clear description of control group, important aspects of study design not reported (e.g., attrition)
Weisz JR, Doss AJ, Hawley KM. Youth psychotherapy outcome research: a review and critique of the evidence base. Annu Rev Psychol. 2005;56:337–363. | Does not report outcomes listed in inclusion criteria
Weisz JR, McCarty CA, Valeri SM. Effects of psychotherapy for depression in children and adolescents: a meta-analysis. Psychol Bull. 2006;132:132–149. | Used as source document only
Weisz JR, Weiss B, Alicke MD, Klotz ML. Effectiveness of psychotherapy with children and adolescents: a meta-analysis for clinicians. J Consult Clin Psychol. 1987;55:542–549. | Does not focus on depression screening or treatment or harms of either
Wells, Karen C. and Albano, Anne Marie. Parent Involvement in CBT Treatment of Adolescent Depression: Experiences in the Treatment for Adolescents With Depression Study (TADS). Cognitive and Behavioral Practice 2005;12(2), 209–220. | Does not report outcomes listed in inclusion criteria
Wernicke JF. Safety and side effect profile of fluoxetine. Expert Opinion on Drug Safety. 2004;3:495–504. | Does not meet criteria for study design
Whittington CJ, Kendall T, Fonagy P, Cottrell D, Cotgrove A, Boddington E. Selective serotonin reuptake inhibitors in childhood depression: systematic review of published versus unpublished data. Lancet. 2004;363:1341–1345. | Used as source document only
Wignall, Ann. Evaluation of a Group CBT Early Intervention Program for Adolescents With Comorbid Depression and Behaviour Problems. Australian Journal of Guidance & Counselling 16[1], 119–132. 2006. | Conducted exclusively in high-risk populations
Wohlfarth, Tamar, Lekkerkerker, Frits, and van Zwieten, Barbara. Use of selective serotonin reuptake inhibitors in childhood depression. Lancet 2004;364(9435), 659–660. | Does not meet criteria for study design
Wong IC, Besag FM, Santosh PJ, Murray ML. Use of selective serotonin reuptake inhibitors in children and adolescents. Drug Saf. 2004;27:991–1000. | Does not meet criteria for study design
Wood A, Harrington R, Moore A. Controlled trial of a brief cognitive-behavioural intervention in adolescent patients with depressive disorders. J Child Psychol Psychiatry. 1996;37:737–746. | Focus on treatment comparison, matching, or fine-tuning
Wright JH, Wright AS, Albano AM, Basco MR, Goldsmith LJ, Raffield T, Otto MW. Computer-assisted cognitive therapy for depression: maintaining efficacy while reducing therapist time. The American journal of psychiatry. 2005;1158–1164. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Young JF, Mufson L, Davies M. Impact of comorbid anxiety in an effectiveness study of interpersonal psychotherapy for depressed adolescents. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:904–912. | Conducted exclusively in high-risk populations
Zimmerman M, Posternak MA, Chelminski I. Derivation of a definition of remission on the Montgomery-Asberg depression rating scale corresponding to the definition of remission on the Hamilton rating scale for depression. J Psychiatr Res. 2004;38:577–582. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Zito JM, Safer DJ. Antidepressant treatment in children and adolescents: bridging the gap between efficacy and effectiveness. Curr Psychiatry Rep. 2001;3:115–125. | Does not meet criteria for study design

Table C7 Evidence Table of Case-Control Studies for Adverse Effects of Selective Serotonin Reuptake Inhibitors in Treating Depression in Children and Adolescents: Key Question 5

Study ID USPSTF quality rating | Setting | Number of participants Exclusions (# and reason) | Proportion participating | Patient characteristics | SSRI(s) studied | Comparison | Followup | Outcome measures | Effect size | Applicability | Comments
Olfson, 2006^1^ Good | Target population: Medicaid beneficiaries with inpatient stay for depression; 6- to 18- year-old cases with any attempt (controls same because of matching) Selection method: Medicaid data files to find patients with inpatient stay for depression, limited to people with ≥1 medication during 2-year observation period Matched 1 case to 1–5 controls by age, sex, race, state, date of discharge, presence of claims for substance abuse disorder, recent suicide attempt, or use of antipsychotic, stimulant, anxiolytic, or mood-stabilizing medication in prior 60 days Used National Death Index records to identify completed suicide | Suicide attempts: 784 cases 3,635 control Completed suicide: 94 cases 435 controls Exclusions: Patients with ≥1 inpatient or ≥2 outpatient claims for pregnancy, bipolar, schizophrenia, other psychoses, mental retardation, dementia/delirium, ineligible for Medicaid benefits in 60 days prior to event or >15 days inpatient in 60 days prior | 100% cases 100% controls | Mean Age: 15.4 (SD 1.8) Female: 74.5% Ethnicity: 73.9% non-Hispanic White Other: Substance abuse history: 10.3% Antipsychotic use: 13.7% Mood stabilizer use: 12.9% Anxiolytic/hypnotic use: 7.2% Stimulant use: 3.8% | Fluoxetine, Paroxetine, Sertraline, Citalopram, Fluvoxamine Other agents: TCAs, Venlafaxine, Mirtazapine, Bupropion, Trazodone, Nefazodone | Any antidepressants vs. no antidepressants Any SSRI vs. no antidepressant All individual agents vs. no antidepressant | Up to 2 years, length of followup differs depending on when discharge was within a 2-year window | Suicide attempt or completed suicide in a 2-year window | Suicide attempts, any antidepressant: 1.52 (1.12, 2.07); risk of attempt increased with sertraline, venlafaxine, or TCA (no OR reported) Completed suicide, any antidepressant: 15.62 (1.65, ∞) Completed suicide, SSRI: 11.26 (0.97, ∞) Proportion of patients on SSRI: Completed suicide: 37.5% No suicide: 7.7% p = 0.005 | Fair | Applicability to primary care limited due to severity of population studies; also, they minimized confounding by severity by studying a sample high-severity sample, but still have issue of confounding within that range

SSRI-Selective Serotonin Reuptake Inhibitor; SD-standard deviation; TCA-tricyclic antidepressant; vs-versus

References

1 Olfson M, Marcus SC, Shaffer D. Antidepressant drug therapy and suicide in severely depressed children and adults: A case-control study. Arch Gen Psychiatry. 2006;63:865-872. [pmid: 16894062].

Table C8 Evidence Table of Cohort Studies for Adverse Effects of Selective Serotonin Reuptake Inhibitors in Treating Depression in Children and Adolescents: Key Question 5

Study ID USPSTF quality rating | Setting | Number of patients | Patient characteristics | SSRI(s) studied | Comparison | Followup | Outcome measures | Results | Comments
Valuck, 2004^1^ Good | Target population: 12- to 18-year-olds who received either a diagnosis of MDD or an antidepressant med (or both) 1/1998 – 3/2003; limited to population with no diagnosis/medication in 12 months prior to index visit or dispensing Selection method: Used medical claims database that included paid claims from 74 managed care plans and 58 million covered lives | 24,119 | Age: 12–18 (56.8% are 16–18) Female: 63.0% Other: 8.0% Medicaid 51.4% from Midwest | TCAs, SSRIs+ Venlafaxine, other Specific agents not specified | Antidepressant treatment (any of 3 categories or multiple categories) vs. no antidepressant | 6 months – 6 years, 3 months Average length 1.36 yrs (SD 9.1 months) | Suicide attempt per ICD code | Hazard ratio (95% CL) from Cox prop. Hazards model, including propensity scores to control for confounding of med with severity, plus other covariates: SSRI vs. no antidepressant: 1.59 (0.89, 2.82) TCA vs. no antidepressant: too little data to estimate Other vs. no antidepressant: 1.03 (0.43, 2.44) Multiple vs. no antidepressant: 1.43 (0.70, 2.89)
Sondergard, 2006^2^ Fair | Target population: Cohort: 10- to 17-year-olds who purchased an antidepressant between 1/1/1995 – 12/31/1999 Controls: 10- to 17-year-olds, excluding those who died or emigrated during observation period | Cohort: 2,311 Control: 50,000 | Other: 57.4% of cohort had psychiatric hospital contact 1.1% of controls had psychiatric hospital contact | Fluoxetine, citalopram, paroxetine, sertraline, fluvoxamine | Those with antidepressant purchase vs. similar-aged youth without antidepressant purchase | Up to 5 years | Death registry record with cause of death as intentional self-harm | Treated with SSRI vs. no SSRI, adjusting for psychiatric care: OR 4.47 (95% CI 0.95, 20.96) | Comparing youth exposed to antidepressants with general pool of youth, controlling for duration of psychiatric contact; did not account for presence of depressive disorders, much less severity of depression
Martin, 2004^3^ Fair-good | Target population: 5- to 29-year-olds with a primary diagnosis of depressive or anxiety disorder who had pharmacy claims data available for study period 1/1/1997 – 12/31/2001 | 87,920 total 49,381 aged 5–19 years | Age: 72% are 15–29 Female: 60% Other: 18.8% severe depression diagnosis 53.6% mild depression diagnosis 27.6% anxiety diagnosis 0.2% inpatient mental health stay | SSRI, TCA, other antidepressants, agents not specified | Youth with antidepressant claim vs. youth without antidepressant claim | Up to 5 years | Presence of 2 or more claims with bipolar diagnosis after depression or anxiety diagnosis established | Rate of conversion to bipolar: [underlined: 5- to 29-year-olds]: 7.7% per year among antidepressant-exposed 2.5% per year among non-exposed Rate ratio 3.1 (95% CI 3.0, 3.2) [underlined: 5- to 14-year-olds:] 8.0% per year antidepressant-exposed 2.7% per year non-exposed Rate ratio 2.9 (95% CI 2.8, 3.1) [underlined: 15- to 29-year-olds:] 7.7% per year antidepressant-exposed 5.6% per year non-exposed Rate ratio 1.4 (95% CI 1.3, 1.5) | Not clear if those with any bipolar diagnosis prior to depression or anxiety diagnosis established were allowed in the sample

SSRI-Selective Serotonin Reuptake Inhibitor; UK-United Kingdom; TCA-tricyclic antidepressant; CI-confidence interval; vs.-versus; MDD-Major Depressive Disorder; SD-standard deviation

References

1 Valuck RJ, Libby AM, Sills MR, Giese AA, Allen RR. Antidepressant treatment and risk of suicide attempt by adolescents with major depressive disorder: a propensity-adjusted retrospective cohort study. CNS Drugs. 2004;18:1119-1132. [pmid: 15581382].

2 Sondergard L, Kvist K, Andersen PK, Kessing LV. Do antidepressants precipitate youth suicide?: a nationwide pharmacoepidemiological study. Eur Child Adolesc Psychiatry. 2006;15:232-240. [pmid: 16502208].

3 Martin A, Young C, Leckman JF, Mukonoweshuro C, Rosenheck R, Leslie D. Age effects on antidepressant-induced manic conversion. Archives of pediatrics & adolescent medicine. 2004;158:773-780. [pmid: 15289250].

Table C9 Studies Excluded from the Review for Key Question 5

Key Question 5: What are the adverse effects of treatment?
Reference | Reason for exclusion*
Andrade C, Bhakta SG, Singh NM. Controversy revisited: selective serotonin reuptake inhibitors in paediatric depression. World Journal of Biological Psychiatry. 2006;7:251–260. | Does not meet criteria for study design
Antidepressants for children and adolescents: an update. Harv Ment Health Lett. 2006;22:4–5. | Does not meet criteria for study design
Apter A, Lipschitz A, Fong R et al. Evaluation of suicidal thoughts and behaviors in children and adolescents taking paroxetine. J Child Adolesc Psychopharmacol. 2006;16:77–90. | Used as a source document only
Aursnes I, Tvete IF, Gaasemyr J, Natvig B. Suicide attempts in clinical trials with paroxetine randomised against placebo. BMC Medicine. 2005;3:14. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Bauer MS, Wisniewski SR, Kogan JN, Marangell LB, Thase ME, Sachs G. Brief report: paroxetine in younger and adult individuals at high risk for suicide. Psychopharmacol Bull. 2006;39:31–37. | Does not focus on depression screening or treatment or harms of either
Beasley CM, Jr., Koke SC, Nilsson ME, Gonzales JS. Adverse events and treatment discontinuations in clinical trials of fluoxetine in major depressive disorder: an updated meta-analysis. Clin Ther. 2000;22:1319–1330. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Berkowitz RI, Fabricatore AN. Obesity, psychiatric status, and psychiatric medications. Psychiatr Clin North Am. 2005;28:39–54. | Does not report outcomes listed in inclusion criteria
Birmaher B, Brent D. Should we use antidepressants for the treatment of major depressive disorder in children and adolescents? Revista Brasileira de Psiquiatria. 2005;27:89–90. | Does not meet criteria for study design
Blockman M. Selective serotonin reuptake inhibitors in children with major depression. S Afr Med J. 2006; 96(6):476–7. | Does not meet criteria for study design
Blumer D, Montouris G, Davies K. The interictal dysphoric disorder: recognition, pathogenesis, and treatment of the major psychiatric disorder of epilepsy. Epilepsy & Behavior. 2004;5:826–840. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Boylan K, Romero S, Birmaher B. Psychopharmacologic treatment of pediatric major depressive disorder. Psychopharmacology (Berl). 2007; 191(1):27–38. | Does not meet criteria for study design
Bridge JA, Barbe RP, Birmaher B, Kolko DJ, Brent DA. Emergent suicidality in a clinical psychotherapy trial for adolescent depression. American Journal of Psychiatry 2005;162(11):2173–5. | Does not meet criteria for study design
Bridge JA, Salary CB, Birmaher B, Asare AG, Brent DA. The risks and benefits of antidepressant treatment for youth depression. Annals of Medicine 2005;37(6):404–12. | Does not meet criteria for study design
Byford S H. Cost-effectiveness analysis of a home based social work intervention for children and adolescents who have deliberately poisoned themselves. The British journal of psychiatry : the journal of mental science. 1999;Vol-62. | Conducted in population that is not comparable to primary care (e.g., high risk conditions not prevalent in primary care populations)
Caballero J, Nahata MC. Selective serotonin-reuptake inhibitors and suicidal ideation and behavior in children. Am J Health Syst Pharm. 2005;62:864–867. | Does not meet criteria for study design
Carpenter, D. J., Lipschitz, A., Fong, R., Krulewicz, S., Wilkinson, C., and Davies, J. Is it appropriate to combine data from children and adolescents in pediatric MDD clinical trials? Poster presented at: New Clinical Drug Evaluation Unit annual meeting. 6-8-2005. Boca Raton, FL. | Does not meet criteria for study design
Center for Drug Evaluation and Research. Statistical Review: Fluoxetine (Prozac). Application Number: 18-936/SE5-064. 1–37. 2001. | Used as a source document only
Chavira DA, Stein MB. Combined psychoeducation and treatment with selective serotonin reuptake inhibitors for youth with generalized social anxiety disorder. Journal of Child & Adolescent Psychopharmacology. 2002;12:47–54. | Does not focus on depression screening or treatment or harms of either
Cheung AH, Emslie GJ, Mayes TL. Review of the efficacy and safety of antidepressants in youth depression. Journal of Child Psychology and Psychiatry. 2005;46:-754. | Used as a source document only
Christensen H, Griffiths KM, Korten A. Web-based cognitive behavior therapy: analysis of site usage and changes in depression and anxiety scores. J Med Internet Res. 2002;4:e3. | Does not focus on depression screening or treatment or harms of either
Cohen D. Should the use of selective serotonin reuptake inhibitors in child and adolescent depression be banned?. Psychotherapy & Psychosomatics. 2007;76:5–14. | Does not meet criteria for study design
Committee on Safety of Medicines. Report of the CSM Expert Working Group on the Safety of Selective Serotonin Reuptake Inhibitor Antidepressants. ii-185. 2004. | Used as a source document only
Committee on Safety of Medicines. Selective serotonin reuptake inhibitors (SSRIs) - overview of regulatory status and CSM advice relating to major depressive disorder (MDD) in children and adolescents: Summary of clinical trials. MHRA . 2005. 2-9-2007. | Used as a source document only
Council of Scientific Affairs (A-05). Safety and Efficacy of Selective Serotonin Reuptake Inhibitors (SSRIs) in Children and Adolescents. 10. 2006. | Does not meet criteria for study design
Culpepper L, Davidson JR, Dietrich AJ, Goodman WK, Kroenke K, Schwenk TL. Suicidality as a possible side effect of antidepressant treatment. J Clin Psychiatry. 2004;65:742–749. | Does not meet criteria for study design
Diller L. Antidepressants and children's depression. Am J Psychiatry. 2005;162:1226–1227. | Does not meet criteria for study design
Doggrell SA. Fluoxetine--do the benefits outweigh the risks in adolescent major depression?. Expert Opinion on Pharmacotherapy. 2005;6:147–150. | Does not meet criteria for study design
Donnelly CL. Pharmacologic treatment approaches for children and adolescents with posttraumatic stress disorder. Child & Adolescent Psychiatric Clinics of North America. 2003;12:251–269. | Does not focus on depression screening or treatment or harms of either
Dubicka B, Hadley S, Roberts C. Suicidal behaviour in youths with depression treated with new-generation antidepressants: Meta-analysis. Br J Psychiatry. 2006;189:393–398. | Used as a source document only
Faedda GL, Baldessarini RJ, Glovinsky IP, Austin NB. Treatment-emergent mania in pediatric bipolar disorder: a retrospective case review. Journal of Affective Disorders. 2004;82:149–158. | Does not focus on depression screening or treatment or harms of either
Fairbanks JM, Gorman JM. Fluvoxamine. 2004:283–90. | Does not focus on depression screening or treatment or harms of either
Fazel, Seena, Grann, Martin, and Goodwin, Guy M. Suicide trends in discharged patients with mood disorders: Associations with selective serotonin uptake inhibitors and comorbid substance misuse. International Clinical Psychopharmacology 2006;21(2), 111–115. | Does not meet criteria for study design
Fichter MM, Kruger R, Rief W, Holland R, Dohne J. Fluvoxamine in prevention of relapse in bulimia nervosa: effects on eating-specific psychopathology. Journal of Clinical Psychopharmacology. 1996;16:9–18. | Does not focus on depression screening or treatment or harms of either
Findling, Robert L., Nucci, Gianluca, Piergies, Antoni A., Gomeni, Roberto, Bartolic, Edward I., Fong, Regan, Carpenter, David J., Leeder, J. Steven, Gaedigk, Andrea, and Danoff, Theodore M. Multiple Dose Pharmacokinetics of Paroxetine in Children and Adolescents with Major Depressive Disorder or Obsessive-Compulsive Disorder. Neuropsychopharmacology 2006;31(6), 1274–1285. | Does not meet criteria for study design
Flores-Suarez LF, Vega-Memije ME, Chanussot-Deprez C. Cutaneous vasculitis during selective serotonin reuptake inhibitor therapy. Am J Med. 2006;119:e1-e3. | Does not meet criteria for study design
Fluvoxamine: new indication. No progress in obsessive-compulsive disorder. Prescrire Int. 2004;13:163–165. | Does not focus on depression screening or treatment or harms of either
Garland EJ, Baerg EA. Amotivational syndrome associated with selective serotonin reuptake inhibitors in children and adolescents. J Child Adolesc Psychopharmacol. 2001;11:181–186. | Does not meet criteria for study design
Geddes J, Butler R. Depressive disorders. Clin Evid. 2002;951–973. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Geller DA, Wagner KD, Emslie G et al. Paroxetine treatment in children and adolescents with obsessive-compulsive disorder: a randomized, multicenter, double-blind, placebo-controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:1387–1396. | Does not focus on depression screening or treatment or harms of either
Gherpelli, Jose Luiz Dias and Esposito, Sandro Blasi. A prospective randomized double blind placebo controlled crossover study of fluoxetine efficacy in the prophylaxis of chronic daily headache in children and adolescents. Arquivos de Neuro-Psiquiatria 2005;63(3-A), 559–563. | Does not focus on depression screening or treatment or harms of either
Gibbons RD, Hur K, Bhaumik DK, Mann JJ. The relationship between antidepressant medication use and rate of suicide. Arch Gen Psychiatry. 2005;62:165–172. | Does not meet criteria for study design
Gibbons RD, Hur K, Bhaumik DK, Mann JJ. The relationship between antidepressant prescription rates and rate of early adolescent suicide. Am J Psychiatry. 2006;163:1898–1904. | Does not meet criteria for study design
Gillette, Daniel W. Desipramine and ibuprofen. Journal of the American Academy of Child & Adolescent Psychiatry 1998;37(11), 1129. | Does not meet criteria for study design
Go FS MEB. Manic behaviors associated with fluoxetine in three 12- to 18-year-olds with obsessive-compulsive disorder. Journal of Child and Adolescent Psychopharmacology. 1998;73–80. | Does not focus on depression screening or treatment or harms of either
Goldney RD. Suicide and antidepressants: what is the evidence? Australian & New Zealand Journal of Psychiatry. 2006;40:381–385. | Does not meet criteria for study design
Goodman, Wayne K., Murphy, Tanya K., and Lazoritz, Martin. Risk of Suicidality During Antidepressant Treatment of Children and Adolescents. Primary Psychiatry 2006;13(1), 43–50. | Does not meet criteria for study design
Goodman, Wayne K., Murphy, Tanya K., and Storch, Eric A. Risk of adverse behavioral effects with pediatric use of antidepressants. Psychopharmacology 2007;191(1), 87–96. | Does not meet criteria for study design
Guaiana, Giuseppe, Andretta, Margherita, Corbari, Letizia, Mirandola, Mersia, Sorio, Adriano, D'Avanzo, Barbara, and Barbui, Corrado. Antidepressant Drug Consumption and Public Health Indicators in Italy, 1955 to 2000. Journal of Clinical Psychiatry 2005;66(6), 750–755. | Does not meet criteria for study design
Gunnell, David and Ashby, Deborah. Antidepressants and suicide: What is the balance of benefit and harm. BMJ: British Medical Journal 2004;329(7456), 34–38. | Does not meet criteria for study design
Gunnell, David and Ashby, Deborah. Rising prescription rate does not mean rising rate of new users: Reply. BMJ: British Medical Journal 2004;329(7463), 461–462. | Does not meet criteria for study design
Gunther T, Holtkamp K, Jolles J, Herpertz-Dahlmann B, Konrad K. The influence of sertraline on attention and verbal memory in children and adolescents with anxiety disorders. Journal of Child & Adolescent Psychopharmacology. 2005;15:608–618. | Does not focus on depression screening or treatment or harms of either
Hadley SJ, Greenberg J, Hollander E. Diagnosis and treatment of body dysmorphic disorder in adolescents. Current Psychiatry Reports. 2002;4:108–113. | Does not meet criteria for study design
Hall WD. How have the SSRI antidepressants affected suicide risk? Lancet. 2006;367:1959–1962. | Does not meet criteria for study design
Harrington R. Randomized trial of a home-based family intervention for children who have deliberately poisoned themselves. J Am Acad Child Adolesc Psychiatry. 1998;512–518. | Does not report outcomes listed in inclusion criteria
Hazell P. Depression in children and adolescents. Evid Based Ment Health. 2003;6:103–104. | Does not meet criteria for study design
Helgason T, Tomasson H, Zoega T. Antidepressants and public health in Iceland. Time series analysis of national data. British Journal of Psychiatry. 2004;184:157–162. | Does not meet criteria for study design
Helping depressed children. Nature. 2004;431:111. | Does not meet criteria for study design
Hollander, Eric, Swanson, Erika, Anagnostou, Evdokia, Phillips, Ann, Chaplin, William, and Wasserman, Stacey. Liquid fluoxetine versus placebo for repetitive behaviors in childhood autism. Progress in Neurotherapeutics and Neuropsychopharmacology 2006;(1):105–113. | Does not focus on depression screening or treatment or harms of either
Irons, Jane. Fluvoxamine in the treatment of anxiety disorders. Neuropsychiatric Disease And Treatment 2005;1(4), 289–299. | Does not focus on depression screening or treatment or harms of either
Isacsson G, Holmgren P, Ahlner J. Selective serotonin reuptake inhibitor antidepressants and the risk of suicide: a controlled forensic database study of 14,857 suicides. Acta Psychiatrica Scandinavica 2005;111(4):286–90. | Does not meet criteria for study design
James A. The use of Selective Serotonin Re-uptake Inhibitors (SSRIs) in the treatment of depressive disorders in children and adolescents. Epidemiol Psichiatr Soc. 2005;14:63–67. | Does not meet criteria for study design
Jellinek MS. Making safety data available. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:1189. | Does not meet criteria for study design
Jick H, Kaye JA, Jick SS. Antidepressants and the risk of suicidal behaviors. JAMA 2004;292:338–343. | Focus on treatment comparison, matching, or fine-tuning
Jureidini JN, Doecke CJ, Mansfield PR, Haby MM, Menkes DB, Tonkin A L. Efficacy and safety of antidepressants for children and adolescents. BMJ. 2004;328:879–883. | Does not meet criteria for study design
Kamijima K, Murasaki M, Asai M et al. Paroxetine in the treatment of obsessive-compulsive disorder: randomized, double-blind, placebo-controlled study in Japanese patients. Psychiatry & Clinical Neurosciences. 2004;58:427–433. | Does not focus on depression screening or treatment or harms of either
Kaplan A, Hollander E. A review of pharmacologic treatments for obsessive-compulsive disorder. Psychiatr Serv. 2003;54:1111–1118. | Does not focus on depression screening or treatment or harms of either
Klein DN, Dougherty LR, Olino TM. Toward guidelines for evidence-based assessment of depression in children and adolescents. J Clin Child Adolesc Psychol. 2005;34:412–432. | Does not meet criteria for study design
Kolevzon A, Mathewson KA, Hollander E. Selective serotonin reuptake inhibitors in autism: a review of efficacy and tolerability. J Clin Psychiatry. 2006;67:407–414. | Does not focus on depression screening or treatment or harms of either
Kondro W, Sibbald B. Drug company experts advised staff to withhold data about SSRI use in children. CMAJ Canadian Medical Association Journal. 2004;170:783. | Does not meet criteria for study design
Kramer G. Broadening the perspective: treating the whole patient. Epilepsia. 2003;44:Suppl-22. | Does not meet criteria for study design
Kratochvil, Christopher J., Simons, Anne, Vitiello, Benedetto, Walkup, John, Emslie, Graham, Rosenberg, David, and March, John S. A Multisite Psychotherapy and Medication Trial for Depressed Adolescents: Background and Benefits. Cognitive and Behavioral Practice 2005;12(2), 159–165. | Does not meet criteria for study design
Krulewicz S, Carpenter DJ, Fong R et al. Analysis of electrocardiographic data following use of paroxetine in pediatric depression and obsessive-compulsive disorder. Journal of the American Academy of Child & Adolescent Psychiatry 2006;45(4):422–30. | Does not report outcomes listed in inclusion criteria
Leon AC, Marzuk PM, Tardiff K, Bucciarelli A, Markham PT, Galea S. Antidepressants and youth suicide in New York City, 1999-2002. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:1054–1058. | Does not meet criteria for study design
Leon, Andrew C., Marzuk, Peter M., Tardiff, Kenneth, and Teres, Jedediah J. Paroxetine, Other Antidepressants, and Youth Suicide in New York City: 1993 Through 1998. Journal of Clinical Psychiatry 2004;65(7), 915–918. | Does not meet criteria for study design
Lim CJ, Leckman JF, Young C, Martin A. Antidepressant-induced manic conversion: a developmentally informed synthesis of the literature. Int Rev Neurobiol. 2005;65:25–52. | Does not meet criteria for study design
Ludwig J, Marcotte DE. Anti-depressants, suicide, and drug regulation. Journal of Policy Analysis & Management. 2005;24:249–272. | Does not meet criteria for study design
MacGillivray S, Arroll B, Hatcher S et al. Efficacy and tolerability of selective serotonin reuptake inhibitors compared with tricyclic antidepressants in depression treated in primary care: systematic review and meta-analysis. BMJ. 2003;326:1014–1017. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Mancini C, Van AM, Bennett M, Patterson B, Watson C. Emerging treatments for child and adolescent social phobia: a review. Journal of Child & Adolescent Psychopharmacology. 2005;15:589–607. | Does not focus on depression screening or treatment or harms of either
Mancini J, Thirion X, Masut A et al. Anxiolytics, hypnotics, and antidepressants dispensed to adolescents in a French region in 2002. Pharmacoepidemiol Drug Saf. 2006;15:494–503. | Does not focus on depression screening or treatment or harms of either
Mann JJ, Emslie G, Baldessarini RJ et al. ACNP Task Force report on SSRIs and suicidal behavior in youth. Neuropsychopharmacology. 2006;31:473–492. | Used as a source document only
March JS, Biederman J, Wolkow R et al. Sertraline in children and adolescents with obsessive-compulsive disorder: a multicenter randomized controlled trial. JAMA. 1998;280:1752–1756. | Does not focus on depression screening or treatment or harms of either
March JS, Klee BJ, Kremer CM. Treatment benefit and the risk of suicidality in multicenter, randomized, controlled trials of sertraline in children and adolescents. J Child Adolesc Psychopharmacol. 2006;16:91–102. | Used as a source document only
Marquet RL, Bartelds AI, Kerkhof AJ, Schellevis FG, van der ZJ. The epidemiology of suicide and attempted suicide in Dutch General Practice 1983-2003. BMC Family Practice. 2005;6:45. | Does not focus on depression screening or treatment or harms of either
Martin RM, May M, Gunnell D. Did intense adverse media publicity impact on prescribing of paroxetine and the notification of suspected adverse drug reactions? Analysis of routine databases, 2001-2004. Br J Clin Pharmacol. 2006;61:224–228. | Does not focus on depression screening or treatment or harms of either
Martinez C, Rietbrock S, Wise L et al. Antidepressant treatment and the risk of fatal and non-fatal self harm in first episode depression: nested case-control study. BMJ. 2005;330:389. | Focus on treatment comparison, matching, or fine-tuning
Masi G. Pharmacotherapy of pervasive developmental disorders in children and adolescents. CNS drugs. 2004;18:1031–1052. | Does not focus on depression screening or treatment or harms of either
McElroy SL, Kotwal R, Kaneria R, Keck PE, Jr. Antidepressants and suicidal behavior in bipolar disorder. Bipolar Disorders. 2006;8:t-617. | Does not focus on depression screening or treatment or harms of either
McKeown RE, Cuffe SP, Schulz RM. US suicide rates by age group, 1970-2002: an examination of recent trends. American Journal of Public Health. 2006;96:1744–1751. | Does not meet criteria for study design
McQuillan CT, Rodriguez J. Adolescent suicide: a review of the literature. Bol Asoc Med P R. 2000;92:30–38. | Does not meet criteria for study design
Medicines and Healthcare Products Regulatory Agency. Selective Serotonin reuptake inhibitors (SSRIs): overview of regulatory status and CSM advice relating to major depressive disorder (MDD) in children and adolescents - summary of clinical trials. 1–190. 2003. | Used as a source document only
Moor S, Ann M, Hester M et al. Improving the recognition of depression in adolescence: Can we teach the teachers? J Adolesc. 2007; 30(1):81–95. | Does not focus on depression screening or treatment or harms of either
Mosholder AD, Willy M. Suicidal adverse events in pediatric randomized, controlled clinical trials of antidepressant drugs are associated with active drug treatment: A meta-analysis. (References). Journal of Child and Adolescent Psychopharmacology. 2006;16:-32. | Used as a source document only
Mosholder, Andrew D. and Pamer, Carol A. Postmarketing surveillance of suicidal adverse events with pediatric use of antidepressants. Journal of Child and Adolescent Psychopharmacology 2006;16(1–2), 33–36. | Does not meet criteria for study design
Murphy, Tanya K., Storch, Eric A., and Strawser, Melissa S. Selective Serotonin Reuptake Inhibitor-Induced Behavioral Activation in the PANDAS Subtype. Primary Psychiatry 2006;13(8), 87–89. | Does not focus on depression screening or treatment or harms of either
Najjar F, Price LH. Citalopram and dystonia. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:8–9. | Does not meet criteria for study design
Nakahira H, Tomotake M, Ohmori T. Fluvoxamine induced complex partial seizure in the treatment of bulimia nervosa. General Hospital Psychiatry. 2005;27:148–150. | Does not focus on depression screening or treatment or harms of either
Nardi DA, Barrett S. Potential effects of antidepressant agents on the growth and development of children and adolescents. Journal of Psychosocial Nursing & Mental Health Services 2005;43(1):22–35. | Does not meet criteria for study design
Oldham J. The risk/benefit ratio of psychiatric treatment. Journal of Psychiatric Practice. 2005;11:137. | Does not meet criteria for study design
National Institute for Clinical Excellence. Depression in Children and Young People: Identification and management in primary, community and secondary care. 1–233. 2005. Northhamptonshire, The British Psychological Society. | Used as a source document only
Palermo MT, Curatolo P. Pharmacologic treatment of autism. J Child Neurol. 2004;19:155–164. | Does not focus on depression screening or treatment or harms of either
Papanikolaou K, Richardson C, Pehlivanidis A, Papadopoulou-Daifoti Z. Efficacy of antidepressants in child and adolescent depression: a meta-analytic study. J Neural Transm. 2006;113:399–415. | Used as a source document only
Perlis RH, Beasley CM, Wines JD et al. Treatment-associated suicidal ideation and adverse effects in an open, multicenter trial of fluoxetine for major depressive episodes. SO: Psychotherapy and psychosomatics. 2007;76:40–46. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Pignone, M. P., Gaynes, B. N., Rushton, J. L., Mulrow, C. D., Orleans, C. T., Whitener, B. L., Mills, C., and Lohr, K. N. Screening for Depression. i-D-83. 2002. Rockville, MD, Agency for Healthcare Research and Quality. | Used as a source document only
Plioplys S. Depression in children and adolescents with epilepsy. Epilepsy & Behavior. 2003;4:Suppl-45. | Does not meet criteria for study design
Pravin D, Srinath S, Girimaji S, Seshadri SP. Citalopram and mania. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:791. | Does not meet criteria for study design
Pretorius E. Corticosteroids, depression and the role of serotonin. Rev Neurosci. 2004;15:109–116. | Does not report outcomes listed in inclusion criteria
Ramasubbu R. Cerebrovascular effects of selective serotonin reuptake inhibitors: a systematic review. J Clin Psychiatry. 2004;65:1642–1653. | Does not meet criteria for study design
Ray WA, Meredith S, Thapa PB, Hall K, Murray KT. Cyclic antidepressants and the risk of sudden cardiac death. Clinical Pharmacology & Therapeutics. 2004;75:234–241. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Regan J, Hamer G, Wright A, White C. SSRI and suicide in adolescents. Tenn Med. 2004;97:121–122. | Does not meet criteria for study design
Reseland S, Bray I, Gunnell D. Relationship between antidepressant sales and secular trends in suicide rates in the Nordic countries. British Journal of Psychiatry. 2006;188:354–358. | Does not meet criteria for study design
Rihmer Z, Akiskal H. Do antidepressants t(h)reat(en) depressives? Toward a clinically judicious formulation of the antidepressant-suicidality FDA advisory in light of declining national suicide statistics from many countries. Journal of Affective Disorders. 2006;94:3–13. | Does not meet criteria for study design
Ryan ND. Treatment of depression in children and adolescents. Lancet. 2005;366:933–940. | Does not meet criteria for study design
Rynn M, Wagner KD, Donnelly C et al. Long-term sertraline treatment of children and adolescents with major depressive disorder. Journal of Child & Adolescent Psychopharmacology 2006; 6(1–2):103–16. | Does not meet criteria for study design
Safer DJ. Should selective serotonin reuptake inhibitors be prescribed for children with major depressive and anxiety disorders? Pediatrics. 2006;118:1248–1251. | Does not meet criteria for study design
Safer, Daniel J. and Zito, Julie Magno. Treatment-emergent adverse events from selective serotonin reuptake inhibitors by age group: Children versus adolescents. Journal of Child and Adolescent Psychopharmacology 2006;16(1–2), 159–169. | Used as a source document only
Salerian AJ. Use of selective serotonin reuptake inhibitors in childhood depression. Lancet. 2004;364:660–661. | Does not meet criteria for study design
Scahill L, Hamrin V, Pachler ME. The use of selective serotonin reuptake inhibitors in children and adolescents with major depression. Journal of Child & Adolescent Psychiatric Nursing. 2005;18:86–89. | Does not meet criteria for study design
Scharko AM, Reiner WG. Ssri-induced sexual dysfunction in adolescents. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:1067–1068. | Does not report outcomes listed in inclusion criteria
Scharko AM. Selective serotonin reuptake inhibitor-induced sexual dysfunction in adolescents: a review. Journal of the American Academy of Child & Adolescent Psychiatry. 2004;43:1071–1079. | Does not report outcomes listed in inclusion criteria
Seidel L, Walkup JT. Selective serotonin reuptake inhibitor use in the treatment of the pediatric non-obsessive-compulsive disorder anxiety disorders. Journal of Child & Adolescent Psychopharmacology. 2006;16:171–179. | Does not focus on depression screening or treatment or harms of either
Sharp SC, Hellings JA. Efficacy and safety of selective serotonin reuptake inhibitors in the treatment of depression in children and adolescents: practitioner review. Clinical Drug Investigation. 2006;26:247–255. | Used as a source document only
Shen Y and Center for Drug Evaluation and Research. Statistical reviews: application No. 18-936/SE5-064. 1–39. 2003. | Article covered by an included systematic evidence review
Shirazi E, aghband-Rad J. An open trial of citalopram in children and adolescents with depression. Journal of Child & Adolescent Psychopharmacology. 2005;15:233–239. | Does not meet criteria for study design
Simon GE, Savarino J, Operskalski B, Wang PS. Suicide risk during antidepressant treatment. Am J Psychiatry. 2006;163:41–47. | Does not meet criteria for study design
Sondergard L, Kvist K, Lopez AG, Andersen PK, Kessing LV. Temporal changes in suicide rates for persons treated and not treated with antidepressants in Denmark during 1995-1999. Acta Psychiatr Scand. 2006;114:168–176. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Stein DJ, Ipser JC, Balkom AJ. Pharmacotherapy for social phobia. Cochrane Database of Systematic Reviews. 2004;CD001206. | Does not focus on depression screening or treatment or harms of either
Stein DJ, Kasper S, Andersen EW, Nil R, Lader M. Escitalopram in the treatment of social anxiety disorder: analysis of efficacy for different clinical subgroups and symptom dimensions. Depression & Anxiety. 2004;20:175–181. | Does not focus on depression screening or treatment or harms of either
Stein DJ, Zungu-Dirwayi N, van Der Linden GJ, Seedat S. Pharmacotherapy for posttraumatic stress disorder. Cochrane Database of Systematic Reviews. 2000;CD002795. | Does not focus on depression screening or treatment or harms of either
Suicidal ideas with paroxetine or venlafaxine. Prescrire Int. 2004;13:21. | Does not meet criteria for study design
Szigethy, Eva, Whitton, Sarah W., Levy-Warren, Anna, DeMaso, David Ray, Weisz, John, and Beardslee, William R. Cognitive-Behavioral Therapy for Depression in Adolescents With Inflammatory Bowel Disease: A Pilot Study. Journal of the American Academy of Child & Adolescent Psychiatry 2004;43(12), 1469–1477. | Does not meet criteria for study design
Tiihonen J, Lonnqvist J, Wahlbeck K, Klaukka T, Tanskanen A, Haukka J. Antidepressants and the risk of suicide, attempted suicide, and overall mortality in a nationwide cohort. Arch Gen Psychiatry. 2006;63:1358–1367. | Conducted in population that is not comparable to primary care (e.g., high risk conditions not prevalent in primary care populations)
Tucker P, Beebe KL, Burgin C et al. Paroxetine treatment of depression with posttraumatic stress disorder: effects on autonomic reactivity and cortisol secretion. Journal of Clinical Psychopharmacology. 2004;24:131–140. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Vestergaard P, Rejnmark L, Mosekilde L. Anxiolytics, sedatives, antidepressants, neuroleptics and the risk of fracture. Osteoporos Int. 2006;17:807–816. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Vieweg WV, Pandurangi AK, Anum EA, Lanier JO, Fierro MF, Fernandez A. Toxicology Findings in Child and Adolescent Suicides in Virginia: 1987-2003. Prim Care Companion J Clin Psychiatry. 2006;8:142–146. | Does not meet criteria for study design
Vitiello B. Selective serotonin reuptake inhibitors (SSRIs) in children and adolescents. Journal of Child & Adolescent Psychopharmacology. 2006;16:7–9. | Does not meet criteria for study design
von Knorring, Anne Liis, Olsson, Gunilla Ingrid, Thomsen, Per Hove, Lemming, Ole Michael, and Hulten, Agnes. A randomized, double-blind, placebo-controlled study of citalopram in adolescents with major depressive disorder. Journal of Clinical Psychopharmacology 2006;26(3), 311–315. | Does not meet quality criteria: control group conditions not clearly described, eligibility criteria changed midway through study, important aspects of study design not reported (blinding of outcome assessment)
Wadsworth EJ, Moss SC, Simpson SA, Smith AP. Psychotropic medication use and accidents, injuries and cognitive failures. Human psychopharmacology. 2005;20:391–400. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Wagner KD, Berard R, Stein MB et al. A multicenter, randomized, double-blind, placebo-controlled trial of paroxetine in children and adolescents with social anxiety disorder. Arch Gen Psychiatry. 2004;61:1153–1162. | Does not focus on depression screening or treatment or harms of either
Walkup JT LMRMP. Searching for moderators and mediators of pharmacological treatment effects in children and adolescents with anxiety disorders. J Am Acad Child Adolesc Psychiatry. 2003;13–21. | Does not focus on depression screening or treatment or harms of either
Warning: selective serotonin reuptake inhibitors in children and adolescents. S Afr Med J. 2005; 95(9):660. | Does not meet criteria for study design
Waxmonsky J. Assessment and treatment of attention deficit hyperactivity disorder in children with comorbid psychiatric illness. Curr Opin Pediatr. 2003;15:476–482. | Conducted exclusively in high-risk populations
Weiss, Jeffrey J. and Gorman, Jack M. Antidepressant Adherence and Suicide Risk in Depressed Youth. American Journal of Psychiatry 2005;162(9), 1756–1757. | Does not meet criteria for study design
Weisz JR, Doss AJ, Hawley KM. Youth psychotherapy outcome research: a review and critique of the evidence base. Annu Rev Psychol. 2005;56:337–363. | Does not report outcomes listed in inclusion criteria
Wernicke JF. Safety and side effect profile of fluoxetine. Expert Opinion on Drug Safety. 2004;3:495–504. | Does not meet criteria for study design
Whittington CJ, Kendall T, Fonagy P, Cottrell D, Cotgrove A, Boddington E. Selective serotonin reuptake inhibitors in childhood depression: systematic review of published versus unpublished data. Lancet. 2004;363:1341–1345. | Used as a source document only
Wilens TE, Biederman J, Kwon A et al. A systematic chart review of the nature of psychiatric adverse events in children and adolescents treated with selective serotonin reuptake inhibitors. J Child Adolesc Psychopharmacol. 2003;13:143–152. | Does not meet criteria for study design
Winters NC. Are antidepressants safe for adolescents?. Postgrad Med. 2005;118:33–34. | Does not meet criteria for study design
Wohlfarth T, Storosum J. Later results don't confirm antidepressant suicide link. Nature. 2005;437:1232. | Does not meet criteria for study design
Wohlfarth TD, van Zwieten BJ, Lekkerkerker FJ et al. Antidepressants use in children and adolescents and the risk of suicide. Eur Neuropsychopharmacol. 2006;16:79–83. | Used as a source document only
Wohlfarth, Tamar, Lekkerkerker, Frits, and van Zwieten, Barbara. Use of selective serotonin reuptake inhibitors in childhood depression. Lancet 2004;364(9435), 659–660. | Does not meet criteria for study design
Wong IC, Besag FM, Santosh PJ, Murray ML. Use of selective serotonin reuptake inhibitors in children and adolescents. Drug Saf. 2004;27:991–1000. | Does not meet criteria for study design
Zimmerman M, Posternak MA, Chelminski I. Derivation of a definition of remission on the Montgomery-Asberg depression rating scale corresponding to the definition of remission on the Hamilton rating scale for depression. J Psychiatr Res. 2004;38:577–582. | Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
Zlotnik, Gideon. Letter to the editor. Nordic Journal of Psychiatry 2004;58(2), 175. | Does not meet criteria for study design