# Appendix B Detailed Methods

## Literature Search Strategy

For all key questions (KQs), we used existing systematic evidence reviews and meta-analyses to the extent possible and supplemented with primary systematic literature searches bridging the time period covered by the prior review. Results are presented in a cumulative fashion, incorporating the relevant studies from the prior review. For all key questions, we initially searched for systematic reviews, meta-analyses, and evidence-based guidelines on depression screening, treatment, or associated harms in children and adolescents in the Database of Abstracts of Reviews of Effects (DARE), the Cochrane Database of Systematic Reviews (CDSR), MEDLINE, and PsycINFO from 1998 through May 2006. Subsequent searches specific to each key question supplemented evidence found in the search of reviews and meta-analyses. Two reviewers independently examined all searches for relevance to all key questions.

For KQs 1–3 (addressing screening outcomes, accuracy, and harms), we found no systematic reviews or meta-analyses that met our inclusion criteria. Therefore, we conducted a primary literature search for depression screening in children and adolescents in primary care to cover the time period since the previous USPSTF review (1998 through May 2007) in MEDLINE, PsycINFO, and the Cochrane Collaboration Registry of Clinical Trials (CCRCT) without restrictions on study designs. Search terms are listed in Appendix B, Table B1.

For KQ4, we found one systematic review ^1^ and one meta-analysis ^2^ of SSRI treatment efficacy and adverse effects in children and adolescents that covered the years through 2004. We used these reviews as source documents and bridged their searches for SSRI treatment and harms. Therefore, for KQ4, we searched for RCTs/CCTs of psychotherapy and SSRI treatment in children and adolescents in MEDLINE, PsycINFO, and CCRCT in two separate searches covering 1998 through May 2007 for psychotherapy and 2004 through May 2007 for SSRIs.

For KQ5, we searched for adverse effects of SSRIs and psychotherapeutic treatment, without restrictions on study designs, in two separate searches covering 1990 through May 2007 for psychotherapy and 2004 through May 2007 for SSRIs. Our search period for adverse effects of psychotherapy began in 1990 because harms of treatment were not addressed in the previous USPSTF report.

We also obtained articles from outside experts and through reviewing bibliographies of other relevant articles and systematic reviews. In addition to these searches for published trials, the following sources were searched for unpublished trials of SSRIs: Robert Wood Johnson Foundation, Computer Retrieval of Information on Scientific Projects (CRISP), NARSAD: The Mental Health Research Association, ClinicalStudyResults.org, Current Controlled Trials, GlaxoSmithKline Clinical Trial Register, ClinicalTrials.gov, Eli Lilly and Company Clinical Trial Registry, Australian Clinical Trials Registry, NovartisClinicalTrials.com, Bristol-Myers Squibb Clinical Trial Registry, International Federation of Pharmaceutical Manufacturers and Associations Clinical Trials Portal, Drugs@FDA, European Medicines Agency, Education Resources Information Center (ERIC).

## Inclusion and Exclusion Criteria

We developed the following set of inclusion/exclusion criteria that were applied to the key questions.

[underlined: Populations] : This review addresses children and adolescents aged 7 to 18 in the US and other similarly developed westernized populations (defined as Human Development Index > .90). Currently available screening tools are reported to be appropriate for children ages 7 and older. ^3^ Furthermore, the prevalence of depression among children younger than 6 is estimated to be less than one percent, thus the predictive value of a positive test is likely to be low.

[underlined: Populations with Risk Factors] : We addressed the prevalence of depression among populations with risk factors through a contextual question and also captured studies evaluating screening and treatment among populations with risk factors. We examined studies conducted among populations with the following clinically relevant risk factors recommended by experts who reviewed the work plan for this review: children of depressed parents, prior personal history of a major depressive episode, chronic medical conditions with high prevalence among primary care populations (e.g., asthma), substance abuse, and acute negative life events. After reviewing the evidence for depression screening and treatment in populations with risk factors, the USPSTF decided that the review should not address screening and treatment in high-risk populations separately due to the lack of relevant studies. In the discussion section of this review, however, we do consider this evidence in relation to our findings' applicability to these high-risk populations. We did not examine primary epidemiological studies that identify risk factors for childhood depression. We excluded studies focusing on patients with bipolar disorder or with psychotic disorders, including psychotic depression, as well as patients with severe medical conditions (e.g., cancer) that may interfere with the performance of screening tools or treatment, or are not generally represented in primary care populations. We also excluded studies focusing on identifying parental depression, including post-partum maternal depression.

[underlined: Diseases] : This report includes studies focusing on Major Depressive Disorder or Depression Not Otherwise Specified, as defined by DSM-IV criteria. We also included studies that use a pre-determined cutoff on a screening test to define major depression. We did not address screening or treatment of dysthymia or minor depression, or prevention of depression. We did not address screening specifically for suicide prevention, which has been addressed by a separate USPSTF recommendation. ^3,^ ^4^

[underlined: Settings] : We included studies conducted in primary care or in school-based clinics. In addition, we included studies conducted in nonclinic-based settings (e.g., church or after-school programs) if they were conducted in populations that are comparable to primary care patients. For key questions 4 and 5, which evaluate treatment efficacy and adverse effects, we included trials that were conducted in outpatient mental health clinic settings, but these settings were excluded for KQs 1–3. This report does not address depression screening or treatment in incarcerated populations, drug treatment programs, inpatient settings, or residential settings.

[underlined: Screening interventions] : This review includes only studies of screening instruments that are feasible for primary care settings. Specifically, a screening tool should take no longer than 15 minutes to complete if delivered prior to clinician and patient face-to-face contact (e.g., in the waiting room or in the exam room before clinician entrance), and no longer than five minutes or five questions if used during the face-to-face visit. More general mental health screening tools were included if they had a depression module or were being used to identify depressive illness and related outcomes.

[underlined: Treatment interventions] : We included studies of pharmacological interventions that evaluate SSRIs: fluoxetine, fluvoxamine, paroxetine, sertraline, citalopram, and escitalopram. We excluded studies of tricyclic antidepressants (which were found to be ineffective among children and adolescents in the previous review), monoamine oxidase inhibitors (MAOIs), and electroconvulsive therapy (ECT) or other interventions that are not primary care feasible or referable. We also excluded atypical antidepressants since they are not currently FDA-approved for treating depression in children or adolescents and are not expected to be approved in the near future. This report includes studies evaluating the following types of psychotherapeutic interventions: cognitive-behavioral therapy (CBT), interpersonal psychotherapy (IPT), pure or guided self-help, family support, and parental education. The scope of this review does not include health systems approaches to depression treatment such as collaborative care interventions; however, we consider these areas in the discussion of our findings.

[underlined: Outcomes] : We included the following outcomes if they were reported at six weeks followup time or later. The primary health outcomes of interest were remission from depression, improved depressive symptoms, and recurrence of depression. Additional outcomes of interest included quality of life, global functioning, psychosocial functioning, educational achievement, unplanned pregnancy, substance abuse, improvement in comorbid disorders, change in health status, and reduction in physical complaints. For harms, we focused on death, other serious psychiatric events (such as hospitalization, suicidal ideation, and suicide attempts), triggering symptoms of mania, and discontinuation of medication due to adverse events.

[underlined: Study designs] : For key questions 1 and 4, addressing outcomes of screening and treatment, we included RCTs, CCTs, systematic reviews, and meta-analyses. We excluded non-comparative study designs and comparative effectiveness studies. For psychotherapy trials, we included studies with no treatment, placebo pill, or waitlist control groups. We also accepted clinical monitoring as a control group if there was significantly less interaction time compared to the intervention arm(s) and it was restricted to non-therapeutic content. Nondirective supportive psychotherapy was considered to be a treatment group unless it was described as being significantly less intense (in total minutes of contact) than the intervention arm(s).

For key question 2, addressing the accuracy of screening, we included studies of diagnostic accuracy that reported sensitivity and specificity compared to an independently-assessed criterion standard for MDD or Depression NOS within two months of the screening test. For key questions 3 and 5, evaluating the harms of screening and treatment, we used evidence from RCTs preferentially, then well-designed non-randomized controlled trials and high-quality observational studies with sample sizes of at least 1,000.

[underlined: Quality] : We excluded studies that met criteria for “Poor” quality using the USPSTF design-specific criteria (Appendix B, Table B3).

[underlined: Language] : We excluded non-English language abstracts and articles.

## Article Review and Data Abstraction

We reviewed a total of 5,737 abstracts and 480 complete articles for all KQs (Appendix B, Figure B1). While we conducted three searches to cover depression screening, depression treatment efficacy, and depression treatment harms, we reviewed all abstracts for potential inclusion for any of the KQs. Two investigators independently reviewed all abstracts for KQs 4 and 5. The initial search for KQs 1–3 produced a very high yield (3,418 abstracts). Therefore, we used a modified approach to reviewing these abstracts. One investigator reviewed all the abstracts for KQs 1–3. A second investigator independently reviewed all abstracts from the CCRCT search, the 500 most recently published abstracts from both MEDLINE and PsycINFO, and every fifth abstract in the remaining set for MEDLINE and PsycINFO, representing an additional random subset of 20% that were dual reviewed. Therefore, 1,562 of the 3,418 (46%) screening abstracts were dually reviewed for inclusion or exclusion. There were a total of 22 discrepancies between the two reviewers for the 1,562 dual-reviewed abstracts (1.4%). None of these 22 abstracts were included in the final review; therefore, we feel confident that no relevant articles were missed by having a second investigator dual review only a subset of the abstracts.

Figure B1. Search Results and Article Flow

Two investigators independently reviewed articles against inclusion/exclusion criteria specific for each key question and marked articles for exclusion as soon as an exclusion criterion was met. Included studies that met all criteria were then independently rated for quality by two investigators, using the USPSTF's study design-specific criteria supplemented by the National Institute for Health and Clinical Excellence (NICE) criteria for quality assessment ^5^ (Appendix B, Table B3). The Methods Work Group of the USPSTF has defined a three-category rating of “good,” “fair,” and “poor” based on these criteria. In general, a good study meets all criteria well. A fair study does not meet, or it is not clear that it meets, at least one criterion, but has no known important limitation that could invalidate its results. A poor study has important limitations. Articles were rated as good, fair, or poor by each rater, and disagreements were settled by consensus. Studies receiving a poor final quality rating were excluded from the review. Listings of excluded articles for each key question, along with the reason for exclusion, are in Appendix C, Tables C1, C3, C4, C6, and C9. A list of all exclusion criteria is in Appendix B, Table B2.

There are 4 systematic reviews/meta-analyses and 31 trials (reported in 47 articles) included in this review. We found no studies for KQs 1, 1a, and 3. For KQ2, we found 9 studies reported in 12 articles, 5 of which were included in the previous USPSTF report. KQ4 includes 1 systematic review and 18 trials reported in 29 articles, 3 of which were included in the previous USPSTF report, and KQ5 includes 4 meta-analyses and 13 trials reported in 19 articles, none of which were included in the previous USPSTF report because harms were not addressed. One primary reviewer abstracted relevant information such as study setting, population, screening method, and outcomes into standardized evidence tables for each included article (Appendix C, Tables C2, C5, C7 and C8). A second reviewer checked the abstracted data for accuracy and completeness.

## Data Synthesis

We found no data for KQs 1, 1a, and 3. Data synthesis for KQ2 was qualitative because heterogeneity in the instruments, samples and settings studied did not allow for quantitative synthesis. For psychotherapy trials included in KQs 4 and 5, we did not conduct meta-analyses due to the heterogeneity of the interventions. Instead, we qualitatively summarized our findings in the results text and summary tables. For evidence on the efficacy and adverse effects of SSRIs (KQ4 & 5), binary outcome data for response rate and suicide-related adverse events were pooled across the trials meeting our inclusion and exclusion criteria. We used a recent good-quality systematic review (Bridge et al, 2007) as a source of outcome data for response rate and suicide-related events. Bridge and colleagues used suicide-related event data based on the blinded review of outcomes by suicidology experts from Columbia (the same data used in analyses by the FDA). For newer trials, the authors used methodology similar to the Columbia review. We quality rated all individual trials and compared all data for response outcomes against outcomes reported in published versions of individual trials. This review revealed no discrepancies. We could not analyze the data for suicide-related events since the FDA provided these outcomes to Bridge and colleagues. Heterogeneity tests were performed on outcome results. Authors of previous meta-analyses of these data argued that fixed-effect models are not appropriate for this body of literature. ^6,^ ^7^ Commentators on these previous meta-analyses, however, argued that using this approach is appropriate for adverse event outcomes because the trials are already biased toward finding null effects due to lack of systematic measurement of adverse events, underreporting outcomes, and measurement error.

We agree with the assessment by Bridge and colleagues that these trials are likely to have heterogeneity across studies not accounted for by observed covariates. We used a random-effects model (method of DerSimonian and Laird ^8^ ) to calculate the pooled risk difference. Random-effects approaches generally yield lower risk estimates and wider confidence intervals (resulting in more conservative estimates of efficacy and less conservative estimates of adverse events). In order to incorporate more conservative estimates of adverse events into the review, we included results from meta-analyses using fixed-effects models. We conducted sensitivity analyses recalculating pooled risk differences using a fixed-effects model to understand how this difference in approach would affect results. We focused on the risk difference, instead of relative risk, as the data are more directly applicable to comparing risks and benefits (i.e., calculating and comparing numbers needed to treat or harm). All meta-analyses were conducted using RevMan software v4.2.

## External Review Process

The USPSTF appointed three liaisons to guide the scope and reporting of this review. The work plan for the review was sent to five experts on childhood mental health, whom we asked to comment on the general proposed approach, scope of the review, and adequacy of the identified questions. In addition, five outside experts provided feedback on a draft version of this evidence synthesis.

## USPSTF Involvement

This research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. The authors worked with three USPSTF liaisons at key points throughout the review process to develop and refine the scope, analytic framework, and key questions; to resolve issues around the review process; and to finalize the evidence synthesis. The AHRQ had no role in study selection, quality assessment, or synthesis, although AHRQ staff provided project oversight, reviewed the draft evidence synthesis, and distributed the initial evidence report for external review of content by outside experts, including representatives of professional societies and federal agencies. The final published systematic evidence review was revised based on comments from these external reviewers.

### References

1 Cheung AH, Emslie GJ, Mayes TL. Review of the efficacy and safety of antidepressants in youth depression. [References]. Journal of Child Psychology and Psychiatry. 2005;46:754.
2 Wallace AE, Neily J, Weeks WB, Friedman MJ. A cumulative meta-analysis of selective serotonin reuptake inhibitors in pediatric depression: Did unpublished studies influence the efficacy/safety debate? [References]. Journal of Child and Adolescent Psychopharmacology. 2006;16:58.
3 Sharp LK, Lipsky MS. Screening for depression across the lifespan: a review of measures for use in primary care settings.[see comment]. [Review] [45 refs]. American Family Physician. 2002;66(6):1001-8. [pmid: 12358212].
4 U.S.Preventive Services Task Force. Screening for Suicide Risk: Recommendation and Rationale. 2004. Rockville, MD, Agency for Healthcare Research and Quality.
5 National Institute for Health and Clinical Excellence. ‘The guidelines manual’. National Institute for Health and Clinical Excellence. 2006. London, National Institute for Health and Clinical Excellence.
6 Bridge JA, Iyengar S, Salary CB, et al. Clinical response and risk for reported suicidal ideation and suicide attempts in pediatric antidepressant treatment: a meta-analysis of randomized controlled trials. JAMA. 2007;297:1683-1696. [pmid: 17440145].
7 Kaizar E, Greenhouse J, Seltman H, Kelleher K. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Society for Clinical Trials. 2006;3:73-98.
8 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188. [pmid: 3802833].

## Table B1. Search Strategies

### Systematic Reviews and Meta-Analyses

Databases: Database of Abstracts of Reviews (DARE), the Cochrane Database of Systematic Reviews (CDSR), MEDLINE, PsycINFO

1998 to 2006

1 Search “Depression” OR “Depressive Disorder” OR “Depression, Postpartum” OR “Depressive Disorder, Major” OR “Dysthymic Disorder” OR “Seasonal Affective Disorder” Limits: All Child: 0–18 years, English, Publication Date from 1998 to 2006
2 Search 1 AND systematic.sb
3 Search depression.ti.ab. OR depressed.ti.ab. OR depressive.ti.ab
4 Search child.ti.ab OR children.ti.ab. OR adolescen*.ti.ab. OR teen.ti.ab. OR teens.ti.ab. OR teenage*.ti.ab.
5 Search 3 AND 4
6 Search 5 AND (publisher.sb. OR in process.sb.)
7 Search 6 AND systematic.sb.
8 Search 6 AND (meta-analysis.ti.ab. OR medline.ti.ab. OR systematic*.ti.ab. OR search*.ti.ab.)
9 Search 7 OR 8
10 Search 7 OR 8 Limits: English, Publication Date from 1998 to 2006
11 Search 2 OR 10

### Screening Outcomes, Screening Accuracy, and Screening Adverse Effects (Key Questions 1–3)

Databases: MEDLINE, PsycINFO, Cochrane Central Register of Controlled Trials

1998 to 2006

1 Depressive Disorder/
2 Depressive Disorder, Major/
3 Depression/
4 depress$.ti,ab.
5 1 or 2 or 3 or 4
6 Mass Screening/
7 screen$.ti,ab.
8 case finding.ti,ab.
9 casefinding.ti,ab.
10 child$ depression inventory$.ti,ab.
11 child$ depression scale$.ti,ab.
12 child$ depression rating scale$.ti,ab.
13 child$ self report rating scale$.ti,ab.
14 “mood and feelings questionnaire$”.ti,ab.
15 reynold$ child$ depression.ti,ab.
16 reynold$ adolesc$ depression.ti,ab.
17 kutcher$ adolesc$.ti,ab.
18 “depression scale for children$”.ti,ab.
19 beck depression inventory$.ti,ab.
20 Center for Epidemiologic Studies Depression Scale$.ti,ab.
21 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20
22 5 and 21
23 limit 22 to (“child (6 to 12 years)” or “adolescent (13 to 18 years)”)
24 children$.ti,ab.
25 childhood.ti,ab.
26 teen.ti,ab.
27 teens.ti,ab.
28 teenage$.ti,ab.
29 pediatric$.ti,ab.
30 paediatric$.ti,ab.
31 adolescen$.ti,ab.
32 boys.ti,ab.
33 girls.ti,ab.
34 youth.ti,ab.
35 youths.ti,ab.
36 child.ti,ab.
37 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36
38 22 and 37
39 23 or 38
40 limit 39 to english language
41 limit 40 to yr=“1998 - 2006”

### Treatment Efficacy (Key Question 4)

Databases: MEDLINE, PsycINFO, Cochrane Central Register of Controlled Trials

SSRIs: 2004 to 2006; Psychotherapy: 1998 to 2006

1 Depressive Disorder/
2 Depressive Disorder, Major/
3 Depression/
4 depress$.ti. or (depression or depressive or depressed).ab.
5 1 or 2 or 3 or 4
6 Antidepressive Agents, Second-Generation/
7 Serotonin Uptake Inhibitors/
8 Antidepressive Agents/
9 antidepressant$.ti,ab.
10 antidepressives.ti,ab.
11 antidepressive agent$.ti,ab.
12 antidepressive drug$.ti,ab.
13 selective serotonin reuptake inhibitor$.ti,ab.
14 ssri.ti,ab.
15 ssris.ti,ab.
16 Fluoxetine/
17 fluoxetine.ti,ab.
18 prozac.ti,ab.
19 Fluvoxamine/
20 fluvoxamine.ti,ab.
21 luvox.ti,ab.
22 Paroxetine/
23 paroxetine.ti,ab.
24 paxil.ti,ab.
25 Sertraline/
26 sertraline.ti,ab.
27 zoloft.ti,ab.
28 Citalopram/
29 citalopram.ti,ab.
30 celexa.ti,ab.
31 escitalopram.ti,ab.
32 lexapro.ti,ab.
33 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34 Psychotherapy/
35 Psychotherapy, Brief/
36 Psychotherapy, Group/
37 psychotherap$.ti,ab.
38 Cognitive Therapy/
39 (cognitive adj (therap$ or treatment$ or intervention$)).ti,ab.
40 Behavior Therapy/
41 (behavio$ adj (therap$ or treatment$ or intervention$)).ti,ab.
42 interpersonal therap$.ti,ab.
43 interpersonal intervention$.ti,ab.
44 Self-Help Groups/
45 self help.ti,ab.
46 Family Therapy/
47 family support.ti,ab.
48 parent$ education.ti,ab.
49 Parents/ed [Education]
50 Counseling/
51 Directive Counseling/
52 counsel$.ti,ab.
53 Problem Solving/
54 problem solving.ti,ab.
55 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54
56 5 and 33
57 limit 56 to yr=“2004 - 2006”
58 5 and 55
59 limit 58 to yr=“1998 - 2006”
60 57 or 59
61 limit 60 to (“child (6 to 12 years)” or “adolescent (13 to 18 years)”)
62 children$.ti,ab.
63 child.ti,ab.
64 childhood.ti,ab.
65 teen.ti,ab.
66 teens.ti,ab.
67 teenage$.ti,ab.
68 pediatric$.ti,ab.
69 paediatric$.ti,ab.
70 adolescen$.ti,ab.
71 boys.ti,ab.
72 girls.ti,ab.
73 youth.ti,ab.
74 youths.ti,ab.
75 62 or 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74
76 60 and 75
77 61 or 76
78 limit 77 to (clinical trial or controlled clinical trial or randomized controlled trial)
79 clinical trials/ or controlled clinical trials/ or randomized controlled trials/
80 double-blind method/ or random allocation/ or single-blind method/
81 random$.ti,ab.
82 79 or 80 or 81
83 77 and 82
84 78 or 83
85 limit 84 to english language
86 limit 85 to news
87 85 not 86

### Treatment Adverse Effects (Key Question 5)

Databases: MEDLINE, PsycINFO, Cochrane Central Register of Controlled Trials

SSRIs: 2004 to 2006; Psychotherapy: 1990 to 2006

1 Depressive Disorder/
2 Depressive Disorder, Major/
3 Depression/
4 depress$.ti. or (depression or depressive or depressed).ab.
5 1 or 2 or 3 or 4
6 Antidepressive Agents, Second-Generation/
7 Serotonin Uptake Inhibitors/
8 Antidepressive Agents/
9 antidepressant$.ti,ab.
10 antidepressives.ti,ab.
11 antidepressive agent$.ti,ab.
12 antidepressive drug$.ti,ab.
13 selective serotonin reuptake inhibitor$.ti,ab.
14 ssri.ti,ab.
15 ssris.ti,ab.
16 Fluoxetine/
17 fluoxetine.ti,ab.
18 prozac.ti,ab.
19 Fluvoxamine/
20 fluvoxamine.ti,ab.
21 luvox.ti,ab.
22 Paroxetine/
23 paroxetine.ti,ab.
24 paxil.ti,ab.
25 Sertraline/
26 sertraline.ti,ab.
27 zoloft.ti,ab.
28 Citalopram/
29 citalopram.ti,ab.
30 celexa.ti,ab.
31 escitalopram.ti,ab.
32 lexapro.ti,ab.
33 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34 1 or 3 or 4
35 33 and 34
36 limit 35 to yr=“2004 - 2006”
37 Psychotherapy/
38 Psychotherapy, Brief/
39 Psychotherapy, Group/
40 psychotherap$.ti,ab.
41 Cognitive Therapy/
42 (cognitive adj (therap$ or treatment$ or intervention$)).ti,ab.
43 Behavior Therapy/
44 (behavio$ adj (therap$ or treatment$ or intervention$)).ti,ab.
45 interpersonal therap$.ti,ab.
46 interpersonal intervention$.ti,ab.
47 Self-Help Groups/
48 self help.ti,ab.
49 Family Therapy/
50 family support.ti,ab.
51 parent$ education.ti,ab.
52 Parents/ed [Education]
53 Counseling/
54 Directive Counseling/
55 counsel$.ti,ab.
56 Problem Solving/
57 problem solving.ti,ab.
58 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57
59 5 and 58
60 limit 59 to yr=“1990 - 2006”
61 36 or 60
62 limit 61 to (“child (6 to 12 years)” or “adolescent (13 to 18 years)”)
63 children$.ti,ab.
64 child.ti,ab.
65 childhood.ti,ab.
66 teen.ti,ab.
67 teens.ti,ab.
68 teenage$.ti,ab.
69 pediatric$.ti,ab.
70 paediatric$.ti,ab.
71 adolescen$.ti,ab.
72 boys.ti,ab.
73 girls.ti,ab.
74 youth.ti,ab.
75 youths.ti,ab.
76 63 or 64 or 65 or 66 or 67 or 68 or 69 or 70 or 71 or 72 or 73 or 74 or 75
77 61 and 76
78 62 or 77
79 harm$.ti,ab.
80 (adverse effects or chemically induced or drug effects or mortality or poisoning or toxicity).fs.
81 adverse effect$.ti,ab.
82 adverse event$.ti,ab.
83 adverse reaction$.ti,ab.
84 Adverse Drug Reaction Reporting Systems/
85 Drug Toxicity/
86 Drug Hypersensitivity/
87 Death/
88 death.ti,ab.
89 death$.ti,ab.
90 Suicide/
91 Suicide, Attempted/
92 suicide.ti,ab.
93 suicidal$.ti,ab.
94 mania.ti,ab.
95 manic episode$.ti,ab.
96 overdos$.ti,ab,mh.
97 self damag$.ti,ab.
98 self injur$.ti,ab.
99 self injurious behavior/
100 self inflict$.ti,ab.
101 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100
102 78 and 101
103 Antidepressive Agents, Second-Generation/ae, po, to [Adverse Effects, Poisoning, Toxicity]
104 Serotonin Uptake Inhibitors/ae, po, to [Adverse Effects, Poisoning, Toxicity]
105 Fluoxetine/ae, po, to [Adverse Effects, Poisoning, Toxicity]
106 Fluvoxamine/ae, po, to [Adverse Effects, Poisoning, Toxicity]
107 Paroxetine/ae, po, to [Adverse Effects, Poisoning, Toxicity]
108 Sertraline/ae, po, to [Adverse Effects, Poisoning, Toxicity]
109 Citalopram/ae, po, to [Adverse Effects, Poisoning, Toxicity]
110 103 or 104 or 105 or 106 or 107 or 108 or 109
111 limit 110 to yr=“2004 - 2006”
112 limit 111 to (“child (6 to 12 years)” or “adolescent (13 to 18 years)”
113 111 and 76
114 112 or 113
115 102 or 114
116 limit 115 to english language
117 limit 116 to humans
118 limit 116 to animals
119 118 not 117
120 116 not 119
121 limit 120 to news
122 120 not 121

## Table B2. Exclusion Criteria for Key Questions

### Exclusion Criteria Applied to All Key Questions

Population:

- Focus on adults (>18 years old) or children ages 0–6 or doesn't report pediatric outcomes separately
- Focus on patients with severe medical illnesses (e.g., cancer), bipolar disorder, or psychotic disorder
- Focus on identifying or treating maternal depression (e.g., during pregnancy or post-partum)
- Focus on identifying or treating parental depression
- Conducted in population that is not comparable to primary care (e.g., high risk conditions not prevalent in primary care populations)
- Focus on patients with minor depression or dysthymia or doesn't present MDD outcomes separately
- Conducted exclusively in high-risk populations
- Conducted in non-Westernized population

Setting:

- Not conducted in primary care, school-based clinics, or other setting with primary care-comparable population (e.g., church or after school program)
- Conducted with inpatients, or those in residential treatment or drug treatment programs
- Conducted with incarcerated populations

Design:

- Editorials
- Letters
- Non-comparative studies
- Non-systematic reviews
- Opinions
- Comparative effectiveness studies
- Abstracts

Quality:

- Does not meet quality criteria

No relevant outcomes

Precedes search period

Article covered by an included systematic review

Systematic review used as source document only

Non-English

### Additional Exclusion Criteria Specific to Each Key Question

Key Question 1 - Does screening for depression among children and adolescents in the primary care setting improve health outcomes?

Relevance:

- Does not focus on screening and treatment of depression
- Reports on test that is not relevant to or feasible in primary care setting
- Focus on screening for suicide risk

Setting:

- Conducted in outpatient mental health clinic

Quality:

- Only short-term health outcomes less than six weeks are reported

Key Question 2 - Are depression screening instruments for children and adolescents accurate in identifying depression in primary care or school-based clinics?

Relevance:

- Does not focus on depression screening
- Does not use a credible reference standard or reports on test that is not relevant to or feasible in primary care setting
- Focus on screening for suicide risk

Setting:

- Conducted in outpatient mental health clinic

Design:

- Does not report sensitivity and specificity compared to an independently-assessed criterion standard for MDD or Depression NOS within two months of the screening test

Key Question 3 - What are the harms of screening?

Relevance:

- Does not focus on harms of depression screening
- Focus on screening for suicide risk

Setting:

- Conducted in outpatient mental health clinic

Key Question 4 - Does the treatment of depression (SSRIs and/or psychotherapy) among screen-detected children and adolescents identified in primary care or comparable populations improve health outcomes?

Relevance:

- Does not focus on depression treatment
- Focus on efficacy of tricyclic antidepressants, atypical antidepressants, MAOIs, ECT or other medications/procedures that are not primary care feasible or referable
- Focus on treatment comparison, matching, or fine-tuning
- Examination of non-demographic modifiers (e.g., genetics, personality characteristics)
- Focus on prevention of depression (either universal or among populations with risk factors)
- Focus on health systems approach to depression treatment such as collaborative care interventions

Setting:

- Intervention not primary care feasible or widely available for primary care referral

Design:

- Control group is not significantly less interaction time compared to intervention arm or has therapeutic content, including nondirective supportive therapy

Quality:

- Only short-term health outcomes less than six weeks are reported

Key Question 5 - What are the adverse effects of treatment?

Relevance:

- Does not focus on harms of depression treatment
- Focus on harms of tricyclic antidepressants, atypical antidepressants, MAOIs, ECT or other medications/procedures that are not primary care feasible or referable
- Focus on treatment comparison, matching, or fine-tuning
- Examination of non-demographic modifiers (e.g., genetics, personality characteristics)
- Focus on harms of prevention of depression (either universal or among populations with risk factors)

Setting:

- Focus on harms of intervention that is not primary care feasible or widely available for primary care referral

Design:

- High quality observational study with sample size less than 1,000

Table B3 Quality Rating Criteria

Study Design | United States Preventive Services Task Force quality rating criteria ^1^ | National Institute for Health and Clinical Excellence methodology checklists ^2^
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - The study addresses an appropriate and clearly focused question; - A description of the methodology used is included; - The literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - The study addresses an appropriate and clearly focused question; - The cases and controls are taken from comparable populations; - The same exclusion criteria are used for both cases and controls; - Percentage of each group (cases and controls) that participated in the study is similar and participation is not unacceptably low; - Comparison is made between participants and non-participants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Clearly established that controls are non-cases; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid, and reliable way; - The main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals provided
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept blind about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid, and reliable way; - Percentage of the individuals or clusters recruited into each treatment arm of the study who dropped out before the study was completed is acceptable; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to followup or overall high loss to followup; - Measurements are equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - The study indicates how many of the people asked to take part did so, in each of the groups being studied; - The likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - Percentage of individuals or clusters recruited into each arm of the study who dropped out before the study was completed is acceptable; - Comparison is made between full participants and those lost to follow-up, by exposure status; - The outcomes are clearly defined; - The assessment of outcome is made blind to exposure status; - Where blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - The measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - The main potential confounders are identified and taken into account in the design and analysis; - Confidence intervals provided
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - The nature of the test being studied is clearly specified; - The test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - The test and gold standard are measured independently (blind) of each other; - The test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported

## Hierarchy of research design ^1^

- I Properly conducted randomized controlled trial (RCT)
- II-1: Well-designed controlled trial without randomization
- II-2: Well-designed cohort or case-control analytic study
- II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
- III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees

### References

1 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
2 National Institute for Health and Clinical Excellence. (April 2006). ‘The guidelines manual’. London: National Institute for Health and Clinical Excellence. Available from: www.nice.org.uk.