# Appendix A Terminology and Abbreviations

Akathisia: A movement disorder characterized by a feeling of inner restlessness and a compelling need to be in constant motion as well as by actions such as rocking while standing or sitting, lifting the feet as if marching on the spot and crossing and uncrossing the legs while sitting.

Anhedonia: The inability to gain pleasure from enjoyable experiences.

Cognitive-behavioral therapy (CBT): A general term for a classification of therapies that focus on patterns of thinking and behavior that are maladaptive and the beliefs that underlie them. Specific techniques commonly include keeping a diary of significant events and associated feelings, thoughts and behaviors; questioning and testing assumptions or habits of thoughts that might be unhelpful and unrealistic; gradually facing activities which may have been avoided; and trying out new ways of behaving and reacting. Relaxation and distraction techniques are also commonly included.

Collaborative care: A range of specific components may be included in collaborative care interventions, but at minimum the care of the patient is shared by two providers, usually from different disciplines, in consultation with each other. Interventions may range from simple telephone interventions encouraging treatment plan compliance to complex interventions starting with systematic patient identification and including a team of providers from several disciplines.

Hypomania: A mild, less debilitating form of mania.

Interpersonal therapy (IPT): A short-term supportive psychotherapy that focuses on the connection between interactions between people and the development of a person's emotional well-being. IPT focuses on four general areas: grief, role disputes, role transitions, and interpersonal deficits, emphasizing the ways in which a person's current relationships and social context cause or maintain symptoms.

Mania: An abnormally elevated mood state characterized by such symptoms as inappropriate elation, increased irritability, severe insomnia, grandiose notions, increased speed and/or volume of speech, disconnected and racing thoughts, increased sexual desire, markedly increased energy and activity level, poor judgment, and inappropriate social behavior.

Non-directive supportive therapy: Focuses on establishing a trusting relationship with the therapist, empathy, and reflecting a client's feelings about topics and events discussed rather than teaching specific skills or urging clients to change behavioral patterns other than those the client is attempting to change him or herself.

Preparatory actions to suicidal behavior: The person takes steps to injure him or herself, but is stopped by self or others. This includes steps such as buying a gun with the intent of self-harm, but where no attempt has yet been made at self-harm.

Psychomotor retardation: A slowing down of thought and a reduction of physical movements.

Suicide attempt: Self-injurious behavior associated with some intent to die. Intent can be stated or inferred. No injury needed.

Suicidal behavior: Suicidal ideation, suicide attempt, preparatory act, or suicide death.

Suicidal ideation: Thoughts about wanting to be dead or thoughts about killing oneself, not accompanied by preparatory behavior.

## List of acronyms and abbreviations

Abbreviation/Acronym | Phrase, term, name of instrument
ABFT | Attachment-Based Family Therapy
ADHD | Attention Deficit Hyperactive Disorder
AE | Adverse event
BDI | Beck Depression Inventory
BDI-PC | Beck Depression Inventory-Primary Care Version
BID | Bellevue Index of Depression
BMI | Body mass index
CAS | Child Assessment Schedule
CBCL | Child Behavior Checklist
CBT | Cognitive-Behavioral Therapy
CDRS | Children's Depression Rating Scale
CRRS-R | Children's Depression Rating Scale-Revised
CES-D | Center for Epidemiologic Study-Depression Scale
CES-DC | Center for Epidemiologic Study-Depression Scale for Children
C-GAS | Children's Global Assessment Scale
CGI | Clinical Global Impression Scale
CGI-I | Clinical Global Impression-Improvement Scale
CGI-S | Clinical Global Impression-Severity of Illness
CI | Confidence interval
CIDI | Composite International Diagnostic Interview
CIS-R | Revised Clinical Interview Scale
CM | Clinical monitoring
DAWBA | Development and Well-Being Assessment
DSM-III-R | Diagnostic and Statistical Manual of Mental Disorders-3^rd^ Edition-Revised
DSM-IV | Diagnostic and Statistical Manual of Mental Disorders-4^th^ Edition
FDA | Food and Drug Administration
GAF | Global Assessment of Function
HAM-D | Hamilton Rating Scale for Depression
HRSD | Hamilton Rating Scale for Depression
ICD-10 | International Classification of Diseases-10^th^ revision
ICD-9 | International Classification of Diseases-9^th^ revision
IPT-A | Interpersonal Therapy for Adolescents
ITT | Intention to treat
K-SADS | Kiddie Schedule for Affective Disorders and Schizophrenia
K-SADS-E | Kiddie Schedule for Affective Disorders and Schizophrenia-Epidemiological edition
K-SADS-P | Kiddie Schedule for Affective Disorders and Schizophrenia-Present Version
K-SADS-PL | Kiddie Schedule for Affective Disorders and Schizophrenia-Present and Lifetime Version
LIFE | Longitudinal Interval Followup Evaluation
LOCF | Last observation carried forward
MADRS | Montgomery-Asberg Depression Rating Scale
MDD | Major depressive disorder
MFQ | Mood and Feelings Questionnaire
NARSD | National Alliance for Research on Schizophrenia and Depression
NIMH | National Institute of Mental Health
NNH | Number needed to harm
NNT | Number needed to treat
NPV | Negative predictive value
OCD | Obsessive compulsive disorder
OR | Odds ratio
PHQ-A | Patient Health Questionnaire for Adolescents
PPV | Positive predictive value
PRIME-MD | Primary Care Evaluation of Mental Disorders
RADS | Reynolds Adolescent Depression Scale
RCT | Randomized controlled trial
RD | Risk differential
RR | Relative risk
SAE | Serious adverse event
SAMHSA | Substance Abuse and Mental Health Services Administration
SAS-SR | Social Adjustment Scale-Self-Report
SCAN | Schedules for Clinical Assessment in Neuropsychiatry
SDQ | Strengths and Difficulties Questionnaire
SER | Systematic evidence review
SES | Socioeconomic status
SMFQ | Short Mood and Feelings Questionnaire
SRE | Suicide-related event
SSRI | Selective serotonin reuptake inhibitor
TAU | Treatment as usual
TCA | Tricyclic antidepressant
USPSTF | United States Preventive Services Task Force