# References

1 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. Fourth ed. Washington, DC: American Psychiatric Association; 1994.
2 Ryan ND, Puig-Antich J, Ambrosini P, et al. The clinical picture of major depression in children and adolescents. Arch Gen Psychiatry. 1987;44:854-861. [pmid: 3662742].
3 Costello EJ, Erkanli A, Angold A. Is there an epidemic of child or adolescent depression?. J Child Psychol Psychiatry. 2006;47:1263-1271. [pmid: 17176381].
4 Lewinsohn PM, Rohde P, Seeley JR. Major depressive disorder in older adolescents: prevalence, risk factors, and clinical implications. [Review] [110 refs]. Clinical Psychology Review. 1998;18(7):765-94. [pmid: 9827321].
5 Cheung A. Canadian community health survey: major depressive disorder and suicidality in adolescents. Healthcare Policy. 2006;2(2):76-89. [pmid: 19305706].
6 Whitaker A, Johnson J, Shaffer D, et al. Uncommon troubles in young people: prevalence estimates of selected psychiatric disorders in a nonreferred adolescent population. Arch Gen Psychiatry. 1990;47:487-496. [pmid: 2331210].
7 Johnson JG, Harris ES, Spitzer RL, Williams JB. The patient health questionnaire for adolescents: validation of an instrument for the assessment of mental disorders among adolescent primary care patients. J Adolesc Health. 2002;30:196-204. [pmid: 11869927].
8 Schubiner H, Tzelepis A, Wright K, Podany E. The clinical utility of the Safe Times Questionnaire. J Adolesc Health. 1994;15:374-382. [pmid: 7947851].
9 Winter LB, Steer RA, Jones-Hicks L, Beck AT. Screening for major depression disorders in adolescent medical outpatients with the Beck Depression Inventory for Primary Care. J Adolesc Health. 1999;24:389-394. [pmid: 10401966].
10 Weissman MM, Wolk S, Goldstein RB, et al. Depressed adolescents grown up. JAMA. 1999;281:1707-1713. [pmid: 10328070].
11 Anderson RN, Smith BL. Deaths: leading causes for 2001. Natl Vital Stat Rep. 2003;52:1-85.
12 Shaffer D, Gould MS, Fisher P, et al. Psychiatric diagnosis in child and adolescent suicide. Arch Gen Psychiatry. 1996;53:339-348. [pmid: 8634012].
13 Fergusson DM, Woodward LJ. Mental health, educational, and social role outcomes of adolescents with depression. Arch Gen Psychiatry. 2002;59:225-231. [pmid: 11879160].
14 Lewinsohn PM, Rohde P, Seeley JR, Klein DN, Gotlib IH. Natural course of adolescent major depressive disorder in a community sample: predictors of recurrence in young adults. Am J Psychiatry. 2000;157:1584-1591. [pmid: 11007711].
15 Lynch FL, Clarke GN. Estimating the economic burden of depression in children and adolescents. Am J Prev Med. 2006;31:S143-S151. [pmid: 17175409].
16 Kandel DB, Davies M. Adult sequelae of adolescent depressive symptoms. Arch Gen Psychiatry. 1986;43:255-262. [pmid: 3954545].
17 Fava M, Kendler KS. Major depressive disorder. Neuron. 2000;28:335-341. [pmid: 11144343].
18 Zisook S, Rush AJ, Lesser I, et al. Preadult onset vs. adult onset of major depressive disorder: a replication study. Acta Psychiatr Scand. 2007;115:196-205. [pmid: 17302619].
19 Kovacs M. Presentation and course of major depressive disorder during childhood and later years of the life span. J Am Acad Child Adolesc Psychiatry. 1996;35:705-715. [pmid: 8682751].
20 Birmaher B, Arbelaez C, Brent D. Course and outcome of child and adolescent major depressive disorder. Child Adolesc Psychiatr Clin N Am. 2002;11:619-37. x. [pmid: 12222086].
21 Lewinsohn PM, Rohde P, Klein DN, Seeley JR. Natural course of adolescent major depressive disorder: I. Continuity into young adulthood. J Am Acad Child Adolesc Psychiatry. 1999;38:56-63. [pmid: 9893417].
22 Rao U, Ryan ND, Birmaher B, et al. Unipolar depression in adolescents: clinical outcome in adulthood. J Am Acad Child Adolesc Psychiatry. 1995;34:566-578. [pmid: 7775352].
23 Klein DN, Dougherty LR, Olino TM. Toward guidelines for evidence-based assessment of depression in children and adolescents. J Clin Child Adolesc Psychol. 2005;34:412-432. [pmid: 16026212].
24 Karlsson Linnea, Pelkonen Mirjami, Ruuttu Titta, Kiviruusu Olli, Heila Hannele, Holi Matti, Kettunen Kirsi, Tuisku Virpi, Tuulio-Henriksson Annamari, Torronen Johanna, Marttunen Mauri. Current comorbidity among consecutive adolescent psychiatric outpatients with DSM-IV mood disorders. European Child & Adolescent Psychiatry. 2006;15(4):220-231. [pmid: 16502209].
25 Garber J. Depression in children and adolescents: linking risk research and prevention. Am J Prev Med. 2006;31:S104-S125. [pmid: 17175406].
26 Nemeroff CB, Vale WW. The neurobiology of depression: inroads to treatment and new drug discovery. [Review] [83 refs]. J Clin Psychiatry. 2005;66(Suppl-13).
27 Brown GW, Bifulco A, Harris TO. Life events, vulnerability and onset of depression: some refinements. Br J Psychiatry. 1987;150:30-42. [pmid: 3651696].
28 Palermo TM. Impact of recurrent and chronic pain on child and family daily functioning: a critical review of the literature. J Dev Behav Pediatr. 2000;21:58-69. [pmid: 10706352].
29 Thapar A, Rice F. Twin studies in pediatric depression. Child Adolesc Psychiatr Clin N Am. 2006;15:869-81. viii. [pmid: 16952765].
30 Glowinski AL, Madden PA, Bucholz KK, Lynskey MT, Heath AC. Genetic epidemiology of self-reported lifetime DSM-IV major depressive disorder in a population-based twin sample of female adolescents. J Child Psychol Psychiatry. 2003;44:988-996. [pmid: 14531581].
31 van den Oord EJ, Boomsma DI, Verhulst FC. A study of problem behaviors in 10- to 15-year-old biologically related and unrelated international adoptees. Behav Genet. 1994;24:193-205. [pmid: 7945150].
32 Eley TC, ater-Deckard K, Fombonne E, Fulker DW, Plomin R. An adoption study of depressive symptoms in middle childhood. J Child Psychol Psychiatry. 1998;39:337-345. [pmid: 9670089].
33 Downey G, Coyne JC. Children of depressed parents: an integrative review. Psychol Bull. 1990;108:50-76. [pmid: 2200073].
34 Erermis S, Cetin N, Tamar M, Bukusoglu N, Akdeniz F, Goksen D. Is obesity a risk factor for psychopathology among adolescents?. Pediatrics International. 2004;46(3):296-301. [pmid: 15151546].
35 Axelson DA, Birmaher B. Relation between anxiety and depressive disorders in childhood and adolescence. [Review] [120 refs]. Depression & Anxiety. 2001;14:67-78. [pmid: 11668659].
36 Angold A, Costello EJ, Erkanli A. Comorbidity. J Child Psychol Psychiatry. 1999;40:57-87. [pmid: 10102726].
37 Brady EU, Kendall PC. Comorbidity of anxiety and depression in children and adolescents. Psychol Bull. 1992;111:244-255. [pmid: 1557475].
38 Yuh J, Maloy KA, Kenney KA, Reiss D. General psychiatrists and their patients' children: assessment and prevention. Psychiatric Quarterly. 2006;77(2):97-118. [pmid: 16763770].
39 Sharp LK, Lipsky MS. Screening for depression across the lifespan: a review of measures for use in primary care settings.[see comment]. [Review] [45 refs]. American Family Physician. 2002;66(6):1001-8. [pmid: 12358212].
40 Zuckerbrot RA, Maxon L, Pagar D, Davies M, Fisher PW, Shaffer D. Adolescent depression screening in primary care: feasibility and acceptability. Pediatrics. 2007;119:101-108. [pmid: 17200276].
41 Klein JD, Allan MJ, Elster AB, et al. Improving adolescent preventive care in community health centers. Pediatrics. 2001;107(2):318-27. [pmid: 11158465].
42 Halpern-Felsher BL, Ozer EM, Millstein SG, et al. Preventive services in a health maintenance organization: how well do pediatricians screen and educate adolescent patients?. Archives of Pediatrics & Adolescent Medicine. 2000;154(2):173-9. [pmid: 10665605].
43 Costello EJ, Edelbrock C, Costello AJ, Dulcan MK, Burns BJ, Brent D. Psychopathology in pediatric primary care: the new hidden morbidity. Pediatrics. 1988;82:415-424. [pmid: 3405677].
44 Olson AL, Kelleher KJ, Kemper KJ, Zuckerman BS, Hammond CS, Dietrich AJ. Primary care pediatricians' roles and perceived responsibilities in the identification and management of depression in children and adolescents. Ambul Pediatr. 2001;1:91-98. [pmid: 11888379].
45 Zachrisson HD, Rodje K, Mykletun A. Utilization of health services in relation to mental health problems in adolescents: a population based survey. BMC Public Health. 2006;6:34. [pmid: 16480522].
46 DeBar LL, Clarke GN, O'Connor E, Nichols GA. Treated prevalence, incidence, and pharmacotherapy of child and adolescent mood disorders in an HMO. Ment Health Serv Res. 2001;3:73-89. [pmid: 12109840].
47 Ma J, Lee KV, Stafford RS. Depression treatment during outpatient visits by U.S. children and adolescents.[see comment]. Journal of Adolescent Health. 2005;37:434-442. [pmid: 16310120].
48 Olfson M, Gameroff MJ, Marcus SC, Waslick BD. Outpatient treatment of child and adolescent depression in the United States. Arch Gen Psychiatry. 2003;60:1236-1242. [pmid: 14662556].
49 Stagnitti, MN. Antidepressant Use in the U.S. Civilian Noninstitutionalized Population, 2002. Statistical Brief #77. Agency for Healthcare Research and Quality. 1–7. 2005. Rockville, MD, Agency for Healthcare Research and Quality.
50 Shatin D, Drinkard CR. Ambulatory use of psychotropics by employer-insured children and adolescents in a national managed care organization. Ambul Pediatr. 2002;2:111-119. [pmid: 11926842].
51 Delate T, Gelenberg AJ, Simmons VA, Motheral BR. Trends in the use of antidepressants in a national sample of commercially insured pediatric patients, 1998 to 2002. Psychiatr Serv. 2004;55:387-391. [pmid: 15067149].
52 Vitiello B, Zuvekas SH, Norquist GS. National estimates of antidepressant medication use among U.S. children, 1997-2002. J Am Acad Child Adolesc Psychiatry. 2006;45:271-279. [pmid: 16540811].
53 Nemeroff CB, Kalali A, Keller MB, et al. Impact of publicity concerning pediatric suicidality data on physician practice patterns in the United States. Arch Gen Psychiatry. 2007;2007:466-472. [pmid: 17404123].
54 Thomason, C., Riordan, H. J., Schaeffer, J. A., Slagle, P. K., Cox, K., and Kratochvil, C. J. Antidepressant prescribing practices prior to and after black-box warnings. American Academy of Child and Adolescent Psychiatry 53rd Annual Meeting. 2006.
55 Libby AM, Brent DA, Morrato EH, Orton HD, Allen R, Valuck RJ. Decline in Treatment of Pediatric Depression After FDA Advisory on Risk of Suicidality With SSRIs. Am J Psychiatry. 2007;2007:884-891. [pmid: 17541047].
56 McKeown RE, Cuffe SP, Schulz RM. US suicide rates by age group, 1970-2002: an examination of recent trends. American Journal of Public Health. 2006;96:1744-1751. [pmid: 17008567].
57 Hamilton BE, Minino AM, Martin JA, Kochanek KD, Strobino DM, Guyer B. Annual summary of vital statistics: 2005. Pediatrics. 2007;2007:345-360. [pmid: 17272625].
58 Gibbons RD, Brown CH, Hur K, Marcus SM, Bhaumik DK, Mann JJ. Relationship between antidepressants and suicide attempts: an analysis of the veterans health administration data sets. Am J Psychiatry. 2007;164:1044-1049. [pmid: 17606656].
59 MacMillan, H. L., Patterson, C. J., and Wathen, C. N. Screening for depression in primary care: updated recommendations from the canadian task force on preventive health care. Canadian Task Force on Preventive Health Care, 1–11. 2004. London, Ontario.
60 Lock James, Walker Leslie R, Rickert Vaughn I, Katzman Debra K. Suicidality in adolescents being treated with antidepressant medications and the black box label: Position paper of the Society for Adolescent Medicine. Journal of Adolescent Health. 2005;36(1):92-93. [pmid: 15702497].
61 Pignone, M. P., Gaynes, B. N., Rushton, J. L., Mulrow, C. D., Orleans, C. T., Whitener, B. L., Mills, C., and Lohr, K. N. Screening for Depression. i-D-83. 2002. Rockville, MD, Agency for Healthcare Research and Quality.
62 Simeon JG, Dinicola VF, Ferguson HB, Copping W. Adolescent depression: a placebo-controlled fluoxetine treatment study and follow-up. Prog Neuropsychopharmacol Biol Psychiatry. 1990;14:791-795. [pmid: 2293257].
63 Emslie GJ, Rush AJ, Weinberg WA, et al. A double-blind, randomized, placebo-controlled trial of fluoxetine in children and adolescents with depression. Arch Gen Psychiatry. 1997;54:1031-1037. [pmid: 9366660].
64 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
65 Cheung AH, Emslie GJ, Mayes TL. Review of the efficacy and safety of antidepressants in youth depression. [References]. Journal of Child Psychology and Psychiatry. 2005;46:754.
66 Wallace AE, Neily J, Weeks WB, Friedman MJ. A cumulative meta-analysis of selective serotonin reuptake inhibitors in pediatric depression: Did unpublished studies influence the efficacy/safety debate? [References]. Journal of Child and Adolescent Psychopharmacology. 2006;16:58.
67 National Institute for Health and Clinical Excellence. ‘The guidelines manual’. National Institute for Health and Clinical Excellence. 2006. London, National Institute for Health and Clinical Excellence.
68 Goodman R, Ford T, Simmons H, Gatward R, Meltzer H. Using the Strengths and Difficulties Questionnaire (SDQ) to screen for child psychiatric disorders in a community sample. International Review of Psychiatry. 2003;15(12):166-72. [pmid: 12745328].
69 Canals Josepa, Blade J, Carbajo G, Domenech-Llaberia E. The Beck Depression Inventory: Psychometric characteristics and usefulness in nonclinical adolescents. European Journal of Psychological Assessment. 2001;17(1):63-68.
70 Canals J, Domenech E, Carbajo G, Blade J. Prevalence of DSM-III-R and ICD-10 psychiatric disorders in a Spanish population of 18-year-olds. Acta Psychiatr Scand. 1997;96:287-294. [pmid: 9350958].
71 Canals J, Marti-Henneberg C, Fernandez-Ballart J, Domenech E. A longitudinal study of depression in an urban Spanish pubertal population. Eur Child Adolesc Psychiatry. 1995;4:102-111. [pmid: 7796248].
72 Barrera M Jr, Garrison-Jones CV. Properties of the Beck Depression Inventory as a screening instrument for adolescent depression. J Abnorm Child Psychol. 1988;16:263-273. [pmid: 3403810].
73 Roberts RE, Lewinsohn PM, Seeley JR. Screening for adolescent depression: a comparison of depression scales. J Am Acad Child Adolesc Psychiatry. 1991;30:58-66. [pmid: 2005065].
74 Garrison CZ, Addy CL, Jackson KL, McKeown RE, Waller JL. The CES-D as a screen for depression and other psychiatric disorders in adolescents. J Am Acad Child Adolesc Psychiatry. 1991;30:636-641. [pmid: 1890099].
75 Garrison CZ, Jackson KL, Marsteller F, McKeown R, Addy C. A longitudinal study of depressive symptomatology in young adolescents. J Am Acad Child Adolesc Psychiatry. 1990;29:581-585. [pmid: 2387792].
76 Patton GC, Coffey C, Posterino M, Carlin JB, Wolfe R, Bowes G. A computerised screening instrument for adolescent depression: population-based validation and application to a two-phase case-control study. Social Psychiatry & Psychiatric Epidemiology. 1999;34(3):166-72. [pmid: 10327843].
77 Lewis, G. and Pelosi, A. J. The manual of CIS-R. 1992. London, Institute of Psychiatry.
78 March J, Silva S, Petrycki S, et al. Fluoxetine, cognitive-behavioral therapy, and their combination for adolescents with depression: Treatment for Adolescents With Depression Study (TADS) randomized controlled trial. JAMA. 2004;292:807-820. [pmid: 15315995].
79 Mufson L, Dorta KP, Wickramaratne P, Nomura Y, Olfson M, Weissman MM. A randomized effectiveness trial of interpersonal psychotherapy for depressed adolescents. Arch Gen Psychiatry. 2004;61:577-584. [pmid: 15184237].
80 Keller MB, Ryan ND, Strober M, et al. Efficacy of paroxetine in the treatment of adolescent major depression: a randomized, controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2001;40(7):762-72. [pmid: 11437014].
81 Wagner KD, Ambrosini P, Rynn M, et al. Efficacy of sertraline in the treatment of children and adolescents with major depressive disorder: two randomized controlled trials. JAMA. 2003;290:1033-1041. [pmid: 12941675].
82 Berard Ray, Fong Regan, Carpenter David J, Thomason Christine, Wilkinson Christel. An international, multicenter, placebo-controlled trial of paroxetine in adolescents with major depressive disorder. Journal of Child and Adolescent Psychopharmacology. 2006;16(12):59-75. [pmid: 16553529].
83 Emslie Graham, Wagner Karen Dineen, Kutcher Stan, Krulewicz Stan, Fong Regan, Carpenter David J, Lipschitz Alan, Machin Andrea, Wilkinson Christel. Paroxetine Treatment in Children and Adolescents With Major Depressive Disorder: A Randomized, Multicenter, Double-Blind, Placebo-Controlled Trial. Journal of the American Academy of Child Adolescent Psychiatry. 2006;45(6):709-719.
84 Wagner KD, Jonas J, Findling RL, Ventura D, Saikali K. A double-blind, randomized, placebo-controlled trial of escitalopram in the treatment of pediatric depression. Journal of the American Academy of Child Adolescent Psychiatry. 2006;45(3):280-8.
85 Kennard B, Silva S, Vitiello B, et al. Remission and residual symptoms after short-term treatment in the Treatment of Adolescents with Depression Study (TADS). SO: Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45:1404-1411.
86 Kratochvil C, Emslie G, Silva S, et al. Acute time to response in the Treatment for Adolescents with Depression Study (TADS). SO: Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45:1412-1418.
87 Vitiello B, Rohde P, Silva S, et al. Functioning and quality of life in the Treatment for Adolescents with Depression Study (TADS). SO: Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45:1419-1426.
88 Emslie GJ, Heiligenstein JH, Wagner KD, et al. Fluoxetine for acute treatment of depression in children and adolescents: a placebo-controlled, randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 2002;41:1205-1215. [pmid: 12364842].
89 Wagner KD, Robb AS, Findling RL, Jin J, Gutierrez MM, Heydorn WE. A randomized, placebo-controlled trial of citalopram for the treatment of major depression in children and adolescents.[see comment]. American Journal of Psychiatry. 2004;161(6):1079-83. [pmid: 15169696].
90 Whittington CJ, Kendall T, Fonagy P, Cottrell D, Cotgrove A, Boddington E. Selective serotonin reuptake inhibitors in childhood depression: systematic review of published versus unpublished data. Lancet. 2004;363:1341-1345. [pmid: 15110490].
91 National Collaborating Centre for Mental Health (2005). Depression in Children and Young People: Identification and management in primary, community and secondary care. London: The British Psychological Society and Gaskell.
92 Bridge JA, Iyengar S, Salary CB, et al. Clinical response and risk for reported suicidal ideation and suicide attempts in pediatric antidepressant treatment: a meta-analysis of randomized controlled trials. JAMA. 2007;297:1683-1696. [pmid: 17440145].
93 Donnelly CL, Wagner KD, Rynn M, et al. Sertraline in children and adolescents with major depressive disorder. SO: Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45:1162-1170.
94 Mayes TL, Tao R, Rintelmann JW, et al. Do children and adolescents have differential response rates in placebo-controlled trials of fluoxetine?. CNS Spectrums. 2007;12:147-154. [pmid: 17277715].
95 Guy W. Assessment Manual for Psychopharmacology, 2nd ed., DHEW publication 76–388. Washington, D.C.: US Government Printing Office; 1976.
96 Poznanski E, Mokros H. Children's Depression Rating Scale-Revised (CDRS-R). Los Angeles: Western Psychological Services; 1995.
97 von Knorring Anne Liis, Olsson Gunilla Ingrid, Thomsen Per Hove, Lemming Ole Michael, Hulten Agnes. A randomized, double-blind, placebo-controlled study of citalopram in adolescents with major depressive disorder. Journal of Clinical Psychopharmacology. 2006;26(3):311-315. [pmid: 16702897].
98 Compton SN, March JS, Brent D, Albano AM, Weersing R, Curry J. Cognitive-behavioral psychotherapy for anxiety and depressive disorders in children and adolescents: an evidence-based medicine review. J Am Acad Child Adolesc Psychiatry. 2004;43:930-959. [pmid: 15266189].
99 Cuijpers P, van Straten A, Smits N, Smit F. Screening and early psychological intervention for depression in schools : Systematic review and meta-analysis. Eur Child Adolesc Psychiatry. 2006;15(5):300-7. [pmid: 16572276].
100 Stein RE, Zitner LE, Jensen PS. Interventions for adolescent depression in primary care. Pediatrics. 2006;118:669-682. [pmid: 16882822].
101 Weisz JR, McCarty CA, Valeri SM. Effects of psychotherapy for depression in children and adolescents: a meta-analysis. Psychol Bull. 2006;132:132-149. [pmid: 16435960].
102 Clarke GN RP. Cognitive-behavioral treatment of adolescent depression: efficacy of acute group treatment and booster sessions. J Am Acad Child Adolesc Psychiatry. 1999;272–279.
103 Diamond GS RBDGS. Attachment-based family therapy for depressed adolescents: a treatment development study. J Am Acad Child Adolesc Psychiatry. 2002;1190–1196.
104 Ackerson J. Cognitive bibliotherapy for mild and moderate adolescent depressive symptomatology. J Consult Clin Psychol. 1998;685–690.
105 Kahn J, Kehle T. Comparison of cognitive-behavioral, relaxation, and self-modeling interventions for depression among middle-school students. Psychology Review. 1990;19:196.
106 Lewinsohn P. Cognitive-Behavioral Treatment for depressed adolescents. Behavior Therapy. 1990;21:385-401.
107 Mufson L. Efficacy of interpersonal psychotherapy for depressed adolescents. Arch Gen Psychiatry. 1999;573–579.
108 Rossello J. The efficacy of cognitive-behavioral and interpersonal treatments for depression in Puerto Rican adolescents. J Consult Clin Psychol. 1999;734–745.
109 Stark KD, Reynolds WM, Kaslow NJ. A comparison of the relative efficacy of self-control therapy and a behavioral problem-solving therapy for depression in children. J Abnorm Child Psychol. 1987;15:91-113. [pmid: 3571741].
110 Hammad TA, Laughren T, Racoosin J. Suicidality in pediatric patients treated with antidepressant drugs. Arch Gen Psychiatry. 2006;63:332-339. [pmid: 16520440].
111 Kaizar E, Greenhouse J, Seltman H, Kelleher K. Do antidepressants cause suicidality in children? A Bayesian meta-analysis. Society for Clinical Trials. 2006;3:73-98.
112 Valuck RJ, Libby AM, Sills MR, Giese AA, Allen RR. Antidepressant treatment and risk of suicide attempt by adolescents with major depressive disorder: a propensity-adjusted retrospective cohort study. CNS Drugs. 2004;18:1119-1132. [pmid: 15581382].
113 Sondergard L, Kvist K, Andersen PK, Kessing LV. Do antidepressants precipitate youth suicide?: a nationwide pharmacoepidemiological study. Eur Child Adolesc Psychiatry. 2006;15:232-240. [pmid: 16502208].
114 Olfson M, Marcus SC, Shaffer D. Antidepressant drug therapy and suicide in severely depressed children and adults: A case-control study. Arch Gen Psychiatry. 2006;63:865-872. [pmid: 16894062].
115 Martin A, Young C, Leckman JF, Mukonoweshuro C, Rosenheck R, Leslie D. Age effects on antidepressant-induced manic conversion. Archives of pediatrics & adolescent medicine. 2004;158:773-780. [pmid: 15289250].
116 Mosholder AD, Willy M. Suicidal adverse events in pediatric randomized, controlled clinical trials of antidepressant drugs are associated with active drug treatment: A meta-analysis. Journal of Child and Adolescent Psychopharmacology. 2006;16:32.
117 Mann JJ, Emslie G, Baldessarini RJ, et al. ACNP Task Force report on SSRIs and suicidal behavior in youth. Neuropsychopharmacology. 2006;31:473-492. [pmid: 16319919].
118 Medicines and Healthcare Products Regulatory Agency. Selective Serotonin reuptake inhibitors (SSRIs): overview of regulatory status and CSM advice relating to major depressive disorder (MDD) in children and adolescents - summary of clinical trials. 1–190. 2003.
119 Wohlfarth TD, van Zwieten BJ, Lekkerkerker FJ, et al. Antidepressants use in children and adolescents and the risk of suicide. Eur Neuropsychopharmacol. 2006;16:79-83. [pmid: 16298514].
120 March JS, Klee BJ, Kremer CM. Treatment benefit and the risk of suicidality in multicenter, randomized, controlled trials of sertraline in children and adolescents. J Child Adolesc Psychopharmacol. 2006;16:91-102. [pmid: 16553531].
121 Committee on Safety of Medicines. Report of the CSM Expert Working Group on the Safety of Selective Serotonin Reuptake Inhibitor Antidepressants. ii-185. 2004.
122 Dubicka B, Hadley S, Roberts C. Suicidal behaviour in youths with depression treated with new-generation antidepressants: Meta-analysis. Br J Psychiatry. 2006;189:393-398. [pmid: 17077427].
123 Apter A, Lipschitz A, Fong R, et al. Evaluation of suicidal thoughts and behaviors in children and adolescents taking paroxetine. J Child Adolesc Psychopharmacol. 2006;16:77-90. [pmid: 16553530].
124 Safer Daniel J, Zito Julie Magno. Treatment-emergent adverse events from selective serotonin reuptake inhibitors by age group: Children versus adolescents. Journal of Child and Adolescent Psychopharmacology. 2006;16(12):159-169. [pmid: 16553536].
125 Nilsson M. Safety of subchronic treatment with fluoxetine for major depressive disorder in children and adolescents. Journal of Child and Adolescent Psychopharmacology. 2004;412–417.
126 Emslie G, Kratochvil C, Vitiello B, et al. Treatment for Adolescents with Depression Study (TADS): safety results. SO: Journal of the American Academy of Child and Adolescent Psychiatry. 2006;45:1440-1455.
127 Newman Thomas B. A black-box warning for antidepressants in children?. New England Journal of Medicine. 2004;351(16):1595-1598. [pmid: 15483275].
128 Angold A, Costello EJ, Messer SC, Pickles A, Winder F, Silver D. Development of a short questionnaire for use in epidemiological studies of depression in children and adolescents. Int J Methods Psychiatr Res. 1995;5:237-249.
129 Daviss W Burleson, Birmaher Boris, Melhem Nadine A, Axelson David A, Michaels Shana M, Brent David A. Criterion validity of the Mood and Feelings Questionnaire for depressive episodes in clinic and non-clinic subjects. Journal of Child Psychology and Psychiatry. 2006;47(9):927-934. [pmid: 16930387].
130 Valla JP, Bergeron L, Smolla N. The Dominic-R: a pictorial interview for 6- to 11-year-old children. Journal of the American Academy of Child & Adolescent Psychiatry. 2000;39(1):85-93. [pmid: 10638071].
131 Valla JP, Bergeron L, Berube H, Gaudet N, St-Georges M. A structured pictorial questionnaire to assess DSM-III-R-based diagnoses in children (6–11 years): development, validity, and reliability. J Abnorm Child Psychol. 1994;22:403-423. [pmid: 7963075].
132 Gould MS, Marrocco FA, Kleinman M, et al. Evaluating iatrogenic risk of youth suicide screening programs: a randomized controlled trial. JAMA. 2005;293(13):1635-43. [pmid: 15811983].
133 Pena JB, Caine ED. Screening as an approach for adolescent suicide prevention. Suicide Life Threat Behav. 2006;2006:614-637. [pmid: 17250467].
134 Asarnow JR, Jaycox LH, Anderson M. Depression among youth in primary care models for delivering mental health services. Child Adolesc Psychiatr Clin N Am. 2002;11:477-97. viii. [pmid: 12222079].
135 Asarnow JR, Jaycox LH, Duan N, et al. Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA. 2005;293:311-319. [pmid: 15657324].
136 Clarke G, Debar L, Lynch F, et al. A randomized effectiveness trial of brief cognitive-behavioral therapy for depressed adolescents receiving antidepressant medication. Journal of the American Academy of Child & Adolescent Psychiatry. 2005;44(9):888-98. [pmid: 16113617].
137 Asarnow JR, Jaycox LH, Duan N, et al. Depression and role impairment among adolescents in primary care clinics. Journal of Adolescent Health. 2005;37(6):477-83. [pmid: 16310125].
138 Molenberghs G, Thijs H, Jansen I, et al. Analyzing incomplete longitudinal clinical trial data. Biostatistics. 2004;2004:445-464. [pmid: 15208205].
139 Carpenter, J. and Kenward, M. Missing Data. www.missingdata.org.uk. 2007.
140 Simon GE, Savarino J. Suicide attempts among patients starting depression treatment with medications or psychotherapy. Am J Psychiatry. 2007;164:1029-1034. [pmid: 17606654].
141 Simon GE, Von KM, Rutter CM, Peterson DA. Treatment process and outcomes for managed care patients receiving new antidepressant prescriptions from psychiatrists and primary care physicians. Arch Gen Psychiatry. 2001;58:395-401. [pmid: 11296101].
142 Isacsson G, Holmgren P, Ahlner J. Selective serotonin reuptake inhibitor antidepressants and the risk of suicide: a controlled forensic database study of 14,857 suicides. Acta Psychiatrica Scandinavica. 2005;111(4):286-90. [pmid: 15740464].
143 Leon AC, Marzuk PM, Tardiff K, Bucciarelli A, Markham PT, Galea S. Antidepressants and youth suicide in New York City, 1999-2002. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:1054-1058. [pmid: 16926612].
144 Leon Andrew C, Marzuk Peter M, Tardiff Kenneth, Teres Jedediah J. Paroxetine, Other Antidepressants, and Youth Suicide in New York City: 1993 Through 1998. Journal of Clinical Psychiatry. 2004;65(7):915-918. [pmid: 15291679].
145 Vieweg WV, Pandurangi AK, Anum EA, Lanier JO, Fierro MF, Fernandez A. Toxicology Findings in Child and Adolescent Suicides in Virginia: 1987-2003. Prim Care Companion J Clin Psychiatry. 2006;8:142-146. [pmid: 16912816].
146 Goodyer I, Dubicka B, Wilkinson P et al. Selective serotonin reuptake inhibitors (SSRIs) and routine specialist care with and without cognitive behaviour therapy in adolescents with major depression: randomised controlled trial. BMJ. 2007;2007:Jun.
147 Melvin GA, Tonge BJ, King NJ, Heyne D, Gordon MS, Klimkeit E. A comparison of cognitive-behavioral therapy, sertraline, and their combination for adolescent depression. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:1151-1161. [pmid: 17003660].
148 Bridge JA, Barbe RP, Birmaher B, Kolko DJ, Brent DA. Emergent suicidality in a clinical psychotherapy trial for adolescent depression. American Journal of Psychiatry. 2005;162(11):2173-5. [pmid: 16263860].
149 Cornelius JR, Clark DB, Bukstein OG, Birmaher B, Salloum IM, Brown SA. Acute phase and five-year follow-up study of fluoxetine in adolescents with major depression and a comorbid substance use disorder: a review. Addict Behav. 2005;30:1824-1833. [pmid: 16102905].
150 Deas D. A double-blind, placebo-controlled trial of sertraline in depressed adolescent alcoholics: A pilot study. Human psychopharmacology. 2000;461–469.
151 Solhkhah R, Wilens TE, Daly J, Prince JB, Van Patten SL, Biederman J. Bupropion SR for the treatment of substance-abusing outpatient adolescents with attention-deficit/hyperactivity disorder and mood disorders. Journal of Child & Adolescent Psychopharmacology. 2005;15(5):777-86. [pmid: 16262594].
152 Sanford Mark, Byrne Carolyn, Williams Susan, Atley Sandy, Ridley Ted, Miller Jennifer, Allin Heather. A Pilot Study of a Parent-Education Group for Families Affected by Depression. Canadian Journal of Psychiatry. 2003;48(2):78-86.
153 Rohde P. Impact of comorbidity on a cognitive-behavioral group treatment for adolescent depression. J Am Acad Child Adolesc Psychiatry. 2001;795–802.
154 Young JF, Mufson L, Davies M. Impact of comorbid anxiety in an effectiveness study of interpersonal psychotherapy for depressed adolescents. Journal of the American Academy of Child & Adolescent Psychiatry. 2006;45:904-912. [pmid: 16865032].
155 Barbe Remy P, Bridge Jeffrey A, Birmaher Boris, Kolko David J, Brent David A. Lifetime History of Sexual Abuse, Clinical Presentation, and Outcome in a Clinical Trial for Adolescent Depression. Journal of Clinical Psychiatry. 2004;65(1):77-83. [pmid: 14744173].
156 Stein BD, Jaycox LH, Kataoka SH, et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial. JAMA. 2003;290(5):603-11. [pmid: 12902363].
157 Briggs-Gowan MJ, Horwitz SM, Schwab-Stone ME, Leventhal JM, Leaf PJ. Mental health in pediatric settings: distribution of disorders and factors related to service use. Journal of the American Academy of Child & Adolescent Psychiatry. 2000;39(7):841-9. [pmid: 10892225].
158 Busch B, Biederman J, Cohen LG, et al. Correlates of ADHD among children in pediatric and psychiatric clinics. Psychiatr Serv. 2002;53:1103-1111. [pmid: 12221308].
159 Andrade NN, Hishinuma ES, McDermott JFJ, et al. The National Center on Indigenous Hawaiian Behavioral Health study of prevalence of psychiatric disorders in Native Hawaiian adolescents. [References]. Journal of the American Academy of Child Adolescent Psychiatry. 2006;45:36.
160 Goodwin RD, Messineo K, Bregante A, Hoven CW, Kairam R. Prevalence of probable mental disorders among pediatric asthma patients in an inner-city clinic. Journal of Asthma. 2005;42(8):643-7. [pmid: 16266954].
161 Vila G, Nollet-Clemencon C, de Blic J, Mouren-Simeoni MC, Scheinmann P. Prevalence of DSM IV anxiety and affective disorders in a pediatric population of asthmatic children and adolescents. Journal of Affective Disorders. 2000;58(3):223-31. [pmid: 10802131].
162 Caplan Rochelle, Siddarth Prabha, Gurbani Suresh, Hanson Rebecca, Sankar Ramen, Shields W Donald. Depression and Anxiety Disorders in Pediatric Epilepsy. Epilepsia. 2005;46(5):720-730. [pmid: 15857439].
163 Pynnonen Paivi A, Isometsa Erkki T, Aronen Eeva T, Verkasalo Matti A, Savilahti Erkki, Aalberg Veikko A. Mental Disorders in Adolescents With Celiac Disease. Psychosomatics: Journal of Consultation Liaison Psychiatry. 2004;45(4):325-335.
164 Campo JV, Bridge J, Ehmann M, et al. Recurrent abdominal pain, anxiety, and depression in primary care. Pediatrics. 2004;113(4):817-24. [pmid: 15060233].
165 Chavira DA, Stein MB, Bailey K, Stein MT. Comorbidity of generalized social anxiety disorder and depression in a pediatric primary care sample. Journal of Affective Disorders. 2004;80(23):163-71. [pmid: 15207929].
166 Giaconia RM, Reinherz HZ, Silverman AB, Pakiz B, Frost AK, Cohen E. Traumas and posttraumatic stress disorder in a community population of older adolescents. J Am Acad Child Adolesc Psychiatry. 1995;34:1369-1380. [pmid: 7592275].
167 Hoven CW, Duarte CS, Lucas CP, et al. Psychopathology among New York city public school children 6 months after September 11. Archives of General Psychiatry. 2005;62(5):545-52. [pmid: 15867108].
168 Beck AT. Beck depression inventory. 1961. Philadelphia, PA, Center for Cognitive Therapy.
169 Radloff LS. The CES-D scale: a self-report depression scale for research in the general population. Applied Psychological Measurement. 1977;1:385-401.
170 Fendrich M, Weissman MM, Warner V. Screening for depressive disorder in children and adolescents: validating the Center for Epidemiologic Studies Depression Scale for Children. Am J Epidemiol. 1990;131:538-551. [pmid: 2301363].
171 Kovacs, M. Childrens depression inventory. 1992. North Tonawanda, NY, Multi-Health System.
172 Costello EJ, Angold A. Scales to assess child and adolescent depression: checklists, screens, and nets. J Am Acad Child Adolesc Psychiatry. 1988;27:726-737. [pmid: 3058677].
173 Reynolds, W. M. Reynolds Adolescent Depression Scale. 1986. Odessa, FL, Psychological Assessment Resources.
174 Reynolds, W. M. Reynolds child depression scale. 1989. Odessa, FL, Psychological Assessment Resources.
175 Goodman R, Renfrew D, Mullick M. Predicting type of psychiatric disorder from Strengths and Difficulties Questionnaire (SDQ) scores in child mental health clinics in London and Dhaka. Eur Child Adolesc Psychiatry. 2000;9:129-134. [pmid: 10926063].
176 Hodges K, McKnew D, Cytryn L, Stern L, Kline J. The Child Assessment Schedule (CAS) diagnostic interview: a report on reliability and validity. J Am Acad Child Psychiatry. 1982;21:468-473. [pmid: 7130556].
177 Kessler RC, Ustun TB. The World Mental Health (WMH) Survey Initiative Version of the World Health Organization (WHO) Composite International Diagnostic Interview (CIDI). Int J Methods Psychiatr Res. 2004. 2004;13:93-121.
178 Goodman R, Ford T, Richards H, Gatward R, Meltzer H. The Development and Well-Being Assessment: description and initial validation of an integrated assessment of child and adolescent psychopathology. J Child Psychol Psychiatry. 2000;41:645-655. [pmid: 10946756].
179 Welner Z, Reich W, Herjanic B, Jung KG, Amado H. Reliability, validity, and parent-child agreement studies of the Diagnostic Interview for Children and Adolescents (DICA). J Am Acad Child Adolesc Psychiatry. 1987;26:649-653. [pmid: 3667494].
180 Schwab-Stone M, Fisher P, Piacentini J, Shaffer D, Davies M, Briggs M. The Diagnostic Interview Schedule for Children-Revised Version (DISC-R): II. Test-retest reliability. J Am Acad Child Adolesc Psychiatry. 1993;32:651-657. [pmid: 8496129].
181 Ambrosini PJ. Historical development and present status of the schedule for affective disorders and schizophrenia for school-age children (K-SADS). J Am Acad Child Adolesc Psychiatry. 2000;2000:49-58. [pmid: 10638067].