# Discussion

## Summary of Review Findings

### KQ1

We found no studies that directly examined the efficacy of screening children and adolescents for depression in increasing recognition or treatment of depression, or improving patients' depression. Therefore, we cannot say whether the use of systematic screening improves identification, treatment, and outcomes of depression over standard identification methods.

### KQ2

Although some instruments appear to have better performance characteristics than others, it is difficult to say the degree to which differences are due to the quality of the instrument or the characteristics of the population or study. None of the instruments have been studied in large numbers of patients from a variety of settings, including studies by investigators other than those who developed the questionnaires. Of primary importance to this review, two primary care studies reported sensitivities of 73 and 90 percent, and specificities of 91 and 94 percent, in instruments developed for primary care (the PHQ-A and BDI-PC). Both of these studies examined only adolescents, so no information was found that is directly applicable to younger children. More data were reported in other settings using a variety of instruments, some including younger children (though most were at least 10 years old), with sensitivities ranging from 18 to 100 percent and specificities ranging from 38 to 97 percent, and differed depending on what instrument, cutoff score, and informant source was used.

Data describing the accuracy of using depression screening instruments in younger children remain very limited. Only one study included children younger than ten and reported generally poor sensitivity and did not report specificity. Assessing depression is difficult in young children, who usually lack the reading skills for paper and pencil instruments and who may have difficulty verbalizing their inner experiences. Usually a parent or caregiver is required to assess a child for depression, but data with older children suggests that the addition of self-report instruments substantially improves the accuracy of depressive diagnoses.^68,^ ^128,^ ^129^ A promising instrument is currently being assessed for use in younger children. This instrument uses a pictorial approach to assess the seven commonly seen disorders in young children, including depression. The Dominic involves a series of drawn pictures depicting a character of indeterminate gender named “Dominic” in situations representing the seven disorders assessed.^130,^ ^131^ For example, one picture shows Dominic walking alone and crying, and the interviewer asks “Do you feel sad and depressed most of the time like Dominic?” It also includes 8 pictures that show “Dominic” feeling happy, in a normal situation. The tool takes 10 to 15 minutes to administer. Preliminary data demonstrate adequate test-retest reliability, internal consistency within the set of pictures targeting each disorder, and agreement with clinical judgment. Information on sensitivity and specificity would be valuable on this instrument and other instruments using approaches requiring minimal verbal skills.

### KQ3

We found no studies that examined potential harms of systematic, standardized screening for depression in any setting. One study, however, has examined iatrogenic distress of screening for suicidality and found that assessing suicidality does not increase distress in adolescents.^132^ This is reassuring since screening for suicidality is often a part of depression screening. Another concerning harm would be if the screening test caused a clinician to miss a case of depression that would have otherwise been detected, perhaps by inappropriately lowering their level of clinical suspicion during the clinical encounter. The negative predictive values of the PHQ-A and BDI-PC, however, were 97 to 99 percent, indicating that a low percentage of adolescents with a negative screen would actually have undetected major depression.

The most likely harm of a systematic screening program in primary care would be the allocation of resources to depression screening that may provide more benefit elsewhere. The positive predictive values of the two tools tested in primary care were both 56 percent, indicating that nearly half of patients with positive screening results would actually not meet criteria for MDD. A positive screening test would be a prompt indicating that further diagnostic assessment by a clinician is needed. If the tool were administered in a waiting room setting, then the patient would already have a scheduled appointment and would receive further assessment immediately. The false positive test would therefore use some of the primary healthcare provider's time during the scheduled office visit but not necessarily require costly followup evaluation by a mental health specialist. Other costs to the healthcare system would be related to the time of office staff to administer the test and process results prior to the office visit. Theoretical harms are similar to those that have been discussed for suicide screening programs.^133^ Until systematic depression screening is tested in a controlled manner, however, actual harms to patients or costs to healthcare systems, relative to undetected and untreated depression, cannot be measured.

### KQ4

The quantity of efficacy data from RCTs of interventions treating pediatric MDD is also quite limited, particularly in comparison with the large body of evidence supporting efficacy among adults. Despite this limitation in quantity, good-quality RCTs have been conducted testing SSRIs and psychotherapies among pediatric populations and provide evidence that efficacious interventions are available, although long-term effects are not known. Meta-analyses have consistently found that fluoxetine is efficacious for treating pediatric populations. Fluoxetine has been studied among both children and adolescents aged 7 to 17 years and is the only drug that is approved by the FDA for treating MDD among youth. Available age-stratified meta-analysis results indicate that fluoxetine is efficacious for both children and adolescents. The absolute risk difference is approximately 20 percent for both age groups, which would mean that approximately five children or adolescents with MDD would need to be treated with fluoxetine in order for one to benefit. When combining data from trials of all SSRIs for treating MDD in youth, we found that patients treated with an SSRI were more likely to show a response to treatment than patients treated with placebo pills. These pooled results, however, must be interpreted cautiously. Baseline response rates among placebo-treated patients were quite variable across the trials, and some individual SSRIs do not appear to be efficacious. Furthermore, not all SSRIs have been evaluated in pediatric clinical trials.

Another important clinical consideration is that the SSRI trials focused on response rates instead of remission rates. A lower percentage of patients would be expected to have a full remission from depression symptoms than the percentage that met response criteria. In the two fluoxetine trials that report remission rates, only 20 to 40 percent of patients in the fluoxetine groups met criteria for remission at the end of acute treatment. Thus, the majority of treated patients continued to have residual symptoms, even after treatment.

Efficacy trials were typically set in specialty research clinics and tested how well the interventions would work under closely controlled conditions. Effectiveness trials, set in more “real world” community clinics, provide information about whether the same intervention would work when implemented in more naturalistic settings. Fluoxetine has been studied in one effectiveness trial among adolescents (TADS) and was found to be more effective than placebo. This trial also evaluated combined therapy with fluoxetine plus individual cognitive-behavioral therapy and found that nearly three out of four patients responded to combined therapy, in contrast with only one in three who responded in the placebo group. These results indicate that two to three adolescents would need to be treated with combined CBT + fluoxetine therapy in order for one adolescent to benefit from the therapy.

Results of psychotherapy trials indicate that a variety of psychotherapy types are efficacious among adolescents, including group CBT and IPT-A. IPT-A has been demonstrated to be effective in a school-based health clinic when delivered by social workers and clinical psychologists, leading to greater improvements in clinician-rated depression scores compared to a treatment-as-usual control group. The difference between groups became apparent by the eighth week of the intervention period. This study was conducted among a low-income, Hispanic population. Several previous meta-analyses of psychotherapy trials that have had either broader or narrower inclusion and exclusion criteria than this review have also concluded that psychotherapies can effectively reduce depression symptoms, although they have differed in terms of the magnitude of the effect.

Numerous potential barriers may interfere with delivering effective treatments to depressed youth identified through primary care.^134^ For example, patients and their families may not be receptive to treatment, and if they are, mental health services may not be available for referral. If mental health services are available, clinicians may not use them appropriately. Recent RCTs have evaluated collaborative care models or quality improvement (QI) interventions that try to reduce some of these barriers.^135,^ ^136^ In the Youth Partners in Care Study (YPIC), Asarnow and colleagues tested a quality improvement intervention designed to increased access to evidence-based treatments for adolescents with depression through primary care.^135,^ ^137^ The trial included patients ages 13 to 21 years with elevated depressive symptoms from five different healthcare organizations (42 percent met criteria for MDD). Patients were randomized either to a QI condition or to usual care. The QI condition included having an expert team leader at each site, care managers who supported primary care clinicians with patient evaluation, education, medication, psychosocial treatment, and linkage to specialty mental health services. Care managers were trained in delivering manual-based CBT. After six months, patients in the QI condition reported higher rates of receiving mental health care than patients in usual care (32 vs. 17 percent, p < 0.001), mostly due to increased rates of psychotherapy (32 vs. 21 percent, p = 0.007). Medication treatment was similar across groups (12 and 16 percent). Adolescents in the QI condition also reported lower depressive symptoms, higher mental health-related functioning, and greater satisfaction with mental care.

Clarke and colleagues have recently evaluated a collaborative care intervention that involved individual CBT, consultation between the CBT therapist and the PCP, and brief telephone contacts during a 12-month followup period.^136^ Clarke and colleagues found a small improvement in mental health-related functioning. Youth in both intervention and control groups, however, showed similar rates of improvement in depressive symptoms from baseline. Interestingly, medication compliance was less among patients in the intervention condition.

All but two included trials had attrition, ranging from 3 to 38 percent of randomized patients. Attrition reduces confidence in the results by increasing susceptibility to confounding through loss of the effects of the initial randomization procedure. The most common method of handling missing data was the LOCF method. The LOCF method and other ad hoc approaches to handling missing data have been criticized in recent years.^136,^ ^138^ LOCF is based on the unrealistic assumption that subjects' measurements don't change after dropout. This assumption is particularly problematic in diseases like depression where the effects of treatment may be expected to change over time. Molenberghs et al. show that the LOCF approach produces biased estimates of treatment effect, and the direction and magnitude of the bias depends on the true (but unknown) treatment effects. Since the direction of the bias can go either way, LOCF can't be assumed to be a conservative estimate. In addition, the bias from LOCF exists even if the reasons behind the missing data are completely random. Given these shortcomings of the LOCF method, many advocate for the use of more stable likelihood-based methods such as linear mixed models in combination with sensitivity analyses to test how the results change under various assumptions.^138,^ ^139^

### KQ5

The most conservative estimates from the final results of the FDA analyses indicate that treating youth with antidepressants leads to a two percent absolute increase in risk of experiencing either suicidal ideation or behavior.^110^ No completed suicides are associated with these trials. When data are pooled for individual drugs, they have not yielded statistically significant increases in suicide-related outcomes. That lack of statistically significant effects, however, may be due to lack of power. For fluoxetine, six percent (17/287) of treated patients and 4 percent (11/289) of placebo control patients experienced either suicidal ideation or behavior during a trial, yielding an absolute risk difference of two percent. This result, however, was not statistically significant.

Based on the estimate of increased absolute risk of two percent, in order for one patient to develop suicidality attributable to antidepressant therapy, approximately 50 patients would need to be treated. Authors of several meta-analyses have argued that additional sources of heterogeneity must be incorporated to more accurately assess the true risk of either efficacy or harms. The FDA analyses used fixed-effects models to calculate risk differences and risk ratios. In contrast, Bridge and colleagues used a random-effects model that incorporated additional sources of within and between meta-analysis heterogeneity. This study found that the absolute risk difference was one percent and that the number needed to harm was 112. In either case, available data indicate that a patient is more likely to benefit from treatment than to develop suicidality. Nevertheless, suicidality is an extremely serious condition and could theoretically translate into an increased risk of suicide death (current trial data are insufficient to answer this question). As a result, the overall balance of risk and benefit of treatment with antidepressants is not yet clear.

We included results from large observational studies in our report. Those findings, however, are greatly limited by the potential for confounding by indication and residual confounding. The same patient and disease characteristics that are associated with increased risk of suicidality (e.g., depression severity) may also increase the likelihood that a clinician would choose to treat a patient with an antidepressant. Although the analyses in the observational studies that we included attempted to adjust for depression severity using different methods, the studies all used data from large administrative datasets and did not have precise clinical measurements of depression severity. Recent data reported by Simon and colleagues (2007) illustrate an additional problem of residual confounding.^140^ They reported that patients aged 25 and younger who had been prescribed antidepressants by a psychiatrist have a much higher incidence of suicide attempts before and after starting treatment compared to patients prescribed antidepressants by primary care physicians. In contrast, their previous research demonstrated that depression severity as measured by conventional diagnostic interviews and symptom scales differed only slightly between patients treated by these different providers.^141^ Therefore, even if depression severity can be documented in an observational data set, residual confounding may still be a problem.

Our report did not include findings from autopsy studies of cases of adolescent suicide.^142^–^145^ These studies have documented low rates of antidepressant exposure among adolescents dying by suicide. However, toxicology analyses used in these studies only measure antidepressant levels from the days immediately prior to death, and data were not reported regarding whether or not these patients had been treated with antidepressants in the weeks or months prior to suicide death.

Data are also currently insufficient to determine the role of combined treatment (SSRI plus psychotherapy) on suicide-related adverse events. The TADS trial was the only RCT included in this review that evaluated combined therapy.^78^ Suicide-related adverse events were less common among patients treated with combined therapy (fluoxetine and CBT; 5.6 percent) compared to fluoxetine alone (8.3 percent), and more common than among patients in the placebo control group (3.6 percent), but differences were not statistically significant. The trial was not powered sufficiently to detect differences of these magnitudes, therefore it is uncertain whether or not combined therapy would lead to a slight increase in suicidality compared to placebo if more data from larger numbers of patients were available. The additional TADS safety results reported by Emslie and colleagues (2006) indicate that the suicidality results vary depending on how it is measured.^126^ Two recent comparative efficacy trials have compared combined therapy with SSRI treatment alone and neither found statistically significant differences between groups for suicidality measures.^146,^ ^147^ The decision to treat an individual pediatric patient with an antidepressant should be based on the clinical situation and on guidelines from mental health specialists. Thus, careful consideration must be given to how closely a patient will be able to be monitored, either through the clinical setting or at home, after initiating a therapy.

Harms of psychotherapy have not been systematically reported in trials in the past. Recently, Bridge and colleagues highlighted the importance of assessing suicidality at baseline and during followup assessments in trials of psychotherapy.^148^

Some youth are believed to have an increased risk of becoming depressed, including those with depressed parents, those with chronic medical conditions, those with other mental health conditions, and those who have experienced significant negative life events. Comorbid familial depression may be particularly relevant when considering high-risk screening approaches in family practice settings. While we did identify a few studies that gave some information about depression treatment efficacy in youth with risk factors, a systematic examination of the efficacy of depression treatment in youth with risk factors was beyond the scope of this review. Most studies examining youth with risk factors were either very small,^149^–^151^ or had other methodological problems, such as attrition.^152^ Several studies included the presence of a risk factor in a multivariate model to determine if it influenced the intervention's effectiveness. Two studies examining the effect of anxiety found contradictory results using different interventions; anxiety was related to better depression outcomes with a CBT intervention^153^ and to poorer outcomes with an IPT intervention.^154^ Using a similar analytic approach, youth with a history of sexual abuse had poorer depression outcomes with a CBT intervention than those who did not.^155^ Finally, we also found a study reporting that depressive symptomatology declined in youth with PTSD when they participated in a CBT intervention.^156^

## Limitations

This review focuses on major depressive disorder and does not address evidence to support screening or treatment for dysthymia, minor depression, or other psychiatric disorders in children and adolescents.

Research addressing MDD in children and adolescents is less comprehensive and well developed than that for adults. Unlike the adult literature, no research directly evaluates the benefits of screening (e.g., increased diagnosis, greater treatment initiation, or improved health outcomes) for depression in children and adolescents in primary care. There is also a more limited volume of research on screening instruments, on pharmacological or psychotherapeutic treatments, and on community treatment patterns in children and adolescents compared to research in depressed adults. Research is particularly limited on screening instruments and treatments appropriate for children aged 10 years and younger.

A major concern for mental health care providers and researchers involves unintended adverse effects from depression-related treatment, and possibly screening, in children and adolescents. The majority of available evidence is focused on the impact of antidepressants on suicidality and is derived from short-term randomized controlled trials. These trials do not specifically focus on collecting adverse effects data and are often conducted in highly selected populations. Additionally, the number of patients studied is substantially smaller than studies in adults, which limits the ability to detect rare events such as suicide. Nonetheless, researchers and regulatory agencies have made considerable efforts to perform comprehensive quality analyses to inform the potential short-term risks of suicidality. Longer-term data on suicidality effects and information on other serious adverse effects, particularly mania precipitation, is quite limited. We did not address more common adverse effects associated with antidepressant use that can affect the acceptability of pharmacological treatments and adherence.

While comorbidity is a common feature of depression in children and adolescents, data are too limited to comment on the impact of various comorbid states on treatment outcomes in children and adolescents, which could be important factors in treatment matching.

## Emerging Issues/Next Steps

We have located trials relevant to this report that are not yet completed or published. These are described in Appendix D. We are not aware of any trials that are in progress or are planned that will assess the effect of screening programs on intermediate outcomes (e.g., disease remission). As mentioned in the summary for KQ2, Bergeron and colleagues are conducting a trial on the accuracy of the Dominic Interactive screening tool among 6- to 11-year-olds. Also, Stark and colleagues have conducted a school-based CBT trial among 9- to 13-year-old girls for which results are expected in 2008. Mufson and colleagues are conducting an ongoing trial of IPT versus usual treatment among 125 female adolescents aged 12 to 18 years that is set in a school-based health clinic. Finally, Hunkeler and colleagues are completing a large-scale observational study of 800,000 children and adolescents who were members of the Kaiser Permanente Medical Care program from 1995 to 2003. This study will assess the relationship between antidepressants and suicidal behavior, including completed suicides.

An expert steering committee is currently completing guidelines for assessing and treating adolescent depression in primary care (GLAD-PC). This guideline has used a combination of evidence- and consensus-based methodologies to develop these guidelines. These guidelines are expected to be published soon.

## Future Research

- Large-scale, randomized controlled trials (or well-controlled clinical trials) of primary care or health care system depression screening programs documenting health outcomes (response, remission, and related health, psychological, and social improvements, as well as harms) and rates of diagnosis and treatment initiation would help guide clinicians as to the role of depression screening programs in caring for children and adolescents
- Descriptive epidemiological studies describing the prevalence of MDD (diagnosed and undiagnosed; treated and untreated) in children and adolescents in primary health care settings by age, sex, and race/ethnicity
- Trials comparing depression treatment adherence and outcomes (including benefits achieved and harms avoided or increased) from depression collaborative care management approaches compared with usual clinical care
- Analyses of predictors of treatment that may be relevant to the implementation and sustainability of interventions in primary care, such as patient treatment preference or level of provider training needed for delivering effective interventions
- Comparative effectiveness of pharmacological and non-pharmacological treatments for MDD in children and adolescents, particularly those at high risk for suicidality or non-adherence to pharmacotherapy
- Observational outcomes studies of risks for longer-term outcomes, including mania precipitation, with use of antidepressants, particularly SSRIs

## Conclusions

Although no trials of screening for pediatric MDD were identified, very limited available data suggest that primary care-feasible screening tools have been reasonably accurate in identifying depressed adolescents. Studies are needed to assess whether these findings can be replicated by other research groups in larger studies that include patients from a variety of primary care settings. Data are also limited regarding treatment of MDD among youth, but evidence from RCTs, including some effectiveness trials, indicate that available treatments are effective in improving depression outcomes among adolescents. Thus, it is possible that screening among adolescents could lead to increased detection of depression, earlier detection of depression, and greater or earlier improvement in depression symptoms than if patients had never been screened.

Data describing screening among children are inadequate. Effects of treatment among children also need to be understood better, as data indicate age is a modifier of treatment effects. Treatment of depressed youth with SSRIs is associated with a small increased risk of suicidality and therefore should only be considered if judicious clinical monitoring is possible. Specific treatment should be based on individual patients' needs and on mental health treatment guidelines.

## Acknowledgments

We are grateful for the feedback and guidance provided by our expert consultant and reviewers: Amy Cheung, MD; Greg Clarke, PhD; Lisa Sharp, PhD; Craig Whittington, PhD; Robin Weersing, PhD, and Karen Wagner, MD, PhD.