# Results

## Key Question 1. Does screening for depression among children and adolescents in the primary care setting improve health outcomes?

### Summary of findings

No trials were found that examined health outcomes of depression screening programs in youth.

### Study details

None.

## Key Question 1a. Does screening increase the proportion of patients identified with and/or treated for depression?

### Summary of findings

No trials were found that examined whether screening led to an increased proportion of children or adolescents identified with and/or treated for depression.

### Study details

None.

## Key Question 2. Are depression screening instruments for children and adolescents accurate in identifying depression in primary care or school-based clinics?

### Summary of findings

We identified nine fair-quality studies (reported in 12 publications) of depression screening instrument accuracy in children and adolescents, covering six different depression instruments (Table 6). Two of these studies were conducted in primary care samples, one in a community sample, and six in school samples. Only one study included children younger than ten years of age, and the majority included adolescents 12 years or older. While the large number of instruments and heterogeneity in samples and settings makes generalization across studies difficult, it may explain the wide range of performance characteristics reported (sensitivity ranged from 18 to 100 percent and specificity ranged from 38 to 97 percent).

Table 6 Depression screening instrument accuracy summary for current major depressive disorder

Study | N (completing screen and diagnostic interview) | Instrument | Age range | Sensitivity | Specificity | PPV | NPV | USPSTF Study Quality^a^
Primary care samples
Johnson, 2002^7^ | 241^b^ | PHQ-A positive | 13–18 | 73% | 94% | 56% | 97% | Fair
Winter*, 1999^9^ | 100 | BDI-PC ≥ 4 | 12–17 | 91% | 91% | 55.6% | 98.8% | Fair
Community samples
Goodman, 2003^68^ | | | 5–10 | 54% (p) | NR | NR | NR
Goodman, 2003^68^ | 7,984 | SDQ positive | 11–15 | 33% (c) | NR | NR | NR | Fair
Goodman, 2003^68^ | | | 11–15 | 44% (p) | NR | NR | NR
Goodman, 2003^68^ | | | 11–15 | 63% (c + p) | NR | NR | NR
School samples
Canals, 2001,^69^, 1997,^70^ 1995^71^ | 290 | BDI ≥ 11 | 17–18 | 90% | 86% | 20% | 99.5% | Fair
Canals, 2001,^69^, 1997,^70^ 1995^71^ | | BDI ≥ 16 | | 90% | 96% | 47% | 99.6%
Barrera*, 1988^72^ | 49 | BDI ≥ 11 | 12–17 | 100% | 77% | NR | NR | Fair
Barrera*, 1988^72^ | | BDI ≥ 16 | | 100% | 93% | NR | NR
Whitaker*, 1990^6^ | 356 | BDI ≥ 16 | 14–17 | 77% | 65% | NR | NR | Fair
Roberts*, 1991^73^ | 1,704 | BDI ≥ 11 | Mean age 16.6 | 84% | 81% | 10% | 99.5% | Fair
Roberts*, 1991^73^ | | CES-D ≥ 24 | | 84% | 75% | 8% | 99%
Garrison*, 1991,^74^ 1990^75^ | | CES-D ≥ 22 | 11–15 | 18% (male) | 83% (male) | 9% | NR | Fair
Garrison*, 1991,^74^ 1990^75^ | 332 | | | 83% (female) | 77% (female) | 25% | NR
Garrison*, 1991,^74^ 1990^75^ | | CES-D ≥ 12 | 11–15 | 85% (male) | 49% (male) | 13% | NR
Garrison*, 1991,^74^ 1990^75^ | | | | 84% (female) | 38% (female) | 11% | NR
Patton, 1999^76^ | 170 | CIS-R positive | Mean age 15.7 | 18% | 97% | 49% | 91% | Fair

* Included in 2002 USPSTF report

a USPSTF Quality Criteria are described in Appendix B, Table B3

b 403 patients completed screen and diagnostic interviews, but 162 patients were excluded due to time lag between screen and interview

Abbreviations: c=child, p=parent; NR=not reported; MFQ=Mood and Feelings Questionnaire; SMFQ= Short Mood and Feelings Questionnaire; BDI-PC= Beck Depression Inventory-Primary Care Version; PHQ-A= Patient Health Questionnaire for Adolescents; SDQ= Strengths and Difficulties Questionnaire; CES-DC= Center for Epidemiological Studies-Depression Scale for Children; BDI= Beck Depression Inventory; CES-D= Center for Epidemiological Studies-Depression Scale; CIS-R= Revised Clinical Interview Schedule

Studies involving younger children tended to have poorer performance. One study highlighted the fact that optimal cutoffs may differ for boys and girls. All of the studies had methodological limitations, such as samples with high levels of attrition or nonrandom selection, excessive delays between screening and diagnostic interviews, poor reporting of methods or attrition, small samples, and less-than-ideal reference standards.

Sensitivity in the two primary care studies ranged from 73 percent for the Patient Health Questionnaire for Adolescents (PHQ-A) to 90 percent for the Beck Depression Inventory-Primary Care Version (BDI-PC). Specificity ranged from 91 percent (BDI-PC) to 94 percent (PHQ-A). As both of these studies examined only adolescents, no information was found that is directly applicable to younger children. The single study involving a community sample reported sensitivities ranging from 33 to 63 percent for the Strengths and Difficulties Questionnaire (SDQ), examining various combinations of child-, parent-, and teacher- report with two different age ranges. The 33 percent sensitivity in the SDQ for child-only report in those 11 to 15 years old improved to 63 percent when both parent- and child-report were used. Sensitivity for those 5 to 10 years old (parent-report only) was 53 percent.

Most data were gathered in school settings, which included four studies examining the Beck Depression Inventory (BDI), two examining the Center for Epidemiologic Study-Depression Scale (CES-D), and one examining the Revised Clinical Interview Scale (CIS-R). Cutoffs of both 11 and 16 performed reasonably to very well on the BDI, with sensitivity ranging from 84 to 100 percent (BDI ≥11) or 77 to 100 percent (BDI ≥16), and specificity ranging from 77 to 86 percent (BDI ≥11) or 65 to 96 percent (BDI ≥16). Confidence in these results is quite limited, however, because of methodological problems within each study.

### Study Details

#### Primary care settings

Two fair-quality studies examining the quality of depression instruments were conducted in primary care settings,^7,^ ^9^ one of which was included in the 2002 review.^9^

Johnson et al., 2002: ^7^ This most recent study examined the properties of the Patient Health Questionnaire for Adolescents (PHQ-A), which was designed to assess mood disorders, anxiety, eating disorders, and substance use disorders in adolescent primary care patients. The sample includes 403 adolescents, aged 13 to 18 years, showing no evidence of mental retardation or organic mental disorders, recruited from urban, rural, and suburban primary care sites in California, Ohio, New Jersey, and New York. This study included both office-based and school-based clinics.

After receiving the PHQ-A, a PhD-level psychologist, who was blinded to the results of the PHQ-A, completed a diagnostic interview by phone. Procedures differed between the California sites and the other sites, which resulted in 241 (60 percent) of the 403 completed phone interviews at non-California sites being completed more than 18 days after the PHQ-A. These interviews, therefore, were dropped from the analysis. In contrast, 95 percent of the California sites' phone interviews were completed within one week of the PHQ-A. No data were presented comparing those with complete data, and were subsequently dropped due to this time lag.

This sample was 63.3 percent female, with an average age of 15.9 years. Over three-fourths of the sample was White (77 percent White, 4.2 percent African American, 12.4 percent Hispanic), 9.4 percent of this sample met criteria for MDD according to the diagnostic interview, and 12.4 percent screened positive on the PHQ-A. This study reported sensitivity of 73 percent, specificity of 94 percent, and overall accuracy of 92 percent.

Winter et al., 1999: ^9^ A 1999 study examined the psychometric properties of the Beck Depression Inventory of Primary Care (BDI-PC) in a sample of 12- to 17-year-olds scheduled for routine health maintenance appointments. Investigators recruited 50 boys and 50 girls to complete the BDI-PC in the waiting room prior to an appointment, which required 10 months of recruitment. Pediatricians administered the mood module of the PRIME-MD without seeing BDI-PC responses. The accuracy of pediatricians in assigning mental health diagnoses is unknown, but is likely only fair: kappas of 0.61 and 0.63 have been observed in other studies using similar methodology in adult, primary care providers comparing primary care providers with mental health clinicians, according to the study authors.

The sample in this study was 50 percent female, 73 percent White, 19 percent African American, and 4 percent Hispanic, with an average age of 13.9 years. Eleven percent met criteria for MDD according to the PRIME-MD interview. Using a cutoff of 4, the BDI-PC had both sensitivity and specificity of 91 percent.

#### Community settings

One fair-quality study examined depression screening instruments in a community sample.^68^ This study was not included in the previous USPSTF review.

Goodman et al., 2003: ^68^ This 2003 study examined the Strengths and Difficulties Questionnaire (SDQ) through the British Office of National Statistics.^68^ A sample of 10,438 children was recruited, and parent and teacher reports were attempted for all children. Children were only included if data were complete for all three sources (self, parent, teacher) in 11- to 15-year-olds, and two sources (parent, teacher) in 5- to 10-year-olds (n = 7,984, 76 percent of the children recruited). The SDQ covers common areas of emotional and behavioral difficulties and results in summary scores of “unlikely,” “possible,” and “probable” for conduct-oppositional disorders, hyperactivity-inattention disorders, and anxiety-depressive disorders. After completion of the SDQ, nonclinical interviewers administered a structured diagnostic interview, the Development and Well-Being Assessment (DAWBA). An experienced clinician reviewed the DAWBA and assigned a clinical diagnosis.

Participants were an average age of 10.2 years, and 50.3 percent were female. Children with complete data had slightly lower rates of psychiatric disorders than the full sample. Among those 5 to 10 years old who did not complete a self-report instrument, the sensitivity was 53.9 percent for parent-report SDQ and 69.2 percent when the parent and teacher reports were combined. Specificity was not reported. Among children aged 11 to 15 years, sensitivity for self-report SDQ was 33.3 percent; parent-report was 44.4 percent; parent- and child-report combined was 63 percent; and self-, parent-, and teacher-report combined was 75.9 percent. This study did not report specificity.

#### School settings

Six fair-quality studies in nine publications examined the psychometric properties of depression screening instruments in school settings. Four of the studies examined the Beck Depression Index (BDI),^6,^ ^69^–^73^ two examined the Center for Epidemiologic Studies Depression Scale (CES-D),^73^–^75^ and one examined the Revised Clinical Interview Schedule (CIS-R).^76^ One of the studies examined both the BDI and CES-D.^73^

Canals et al., 2002: ^69^–^71^ The most recent study to examine the BDI was conducted in Spain in a sample of children who had been part of a study 7 years before the current study. Children attending local schools were identified through census records of an urban commercial area of 96,000 inhabitants in Reus, Catalan. Seven years later, they found 304 of the original 579 children and had them complete the Spanish version of the BDI. Of the 304 who completed the BDI, 290 (95 percent) also completed the Schedules for Clinical Assessment in Neuropsychiatry (SCAN) within one week. Participants were not blinded to the BDI results.

The average age of the youth was 18 (range 17.5 to 18.5), and 50 percent were female. The sample had low prevalence of depressive disorders: 3.4 percent were diagnosed with MDD, and 13.1 percent of participants were diagnosed with a depressive disorder of some kind. Researchers reported instrument characteristics using four different cutoffs and assessed accuracy for four different depressive disorders: MDD, DD, adjustment disorder with depressed mood, and depressive disorder not otherwise specified. At the highest cutoff of 16, which had the best PPV, sensitivity was 90 percent, specificity was 96 percent, PPV was 47 percent, and NPV was 99.6 percent for MDD. Although the sensitivity and specificity were very high in this study, confidence in the generalizability of the results is limited by the fact that they only had data on a nonrandom sample of 52 percent of students who had participated in a different study 7 years previous.

Berrera et al., 1988: ^72^ Another study examined the BDI in samples drawn from a school and from youth with inpatient psychiatric admissions. They report results separately for the two samples. We only report the results of the school sample here. Forty-nine youth from a secondary school near the psychiatric facility completed the BDI and, within one week, the semi-structured Child Assessment Schedule (CAS). The authors did not report whether diagnostic interviewers were blinded to BDI results, nor did they describe how the sample was selected from the school.

The school sample had an average age of 14.6 years (range 12 to 17) and was 54 percent female. Five of the 49 participants (10 percent) met criteria for a major depressive episode. They reported instrument characteristics at five different cutoffs for a major depressive episode. At a cutoff of 16, the authors reported a sensitivity of 100 percent and specificity of 93.2 percent, with 6.1 percent false positives. Although sensitivity and specificity were very high in this sample, confidence in the results is limited by the very small sample size, potential lack of blinding, and the lack of description about how the school sample was selected and how many recruited participants refused or were ineligible.

Whitaker et al., 1999: ^6^ The next study to examine the BDI in a school sample looked at performance characteristics in predicting lifetime MDD in the entire enrollment of 9^th^ through 12^th^ grades in a single New Jersey county during October, 1984. Of the 5,596 students enrolled, 5,108 (91 percent) completed the BDI and instruments screening for several other psychiatric disorders during the fall. A stratified random sample of 468 students was selected to complete a semi-structured diagnostic interview the subsequent winter and spring, 356 (76.1 percent) of whom completed the interview. Interviewers did not have access to screening results. Because they oversampled potential cases of several different types of psychiatric disorders, specificity may be underestimated. To adjust for this, they report specificity after excluding all cases of other disorders identified by the screening tool from the false positive results, in addition to the specificity using the entire sample, as it is traditionally calculated.

Characteristics of the larger screening sample were reported. The authors also reported that diagnostic interview completion was not related to sex, age, social class, or BMI. The screening sample was 49.8 percent female, 94 percent White, and 92 percent were between ages 14 and 17. High school was the highest level of educational attainment for 42 percent of the mothers, and 34 percent of the fathers completed high school and had no schooling beyond high school. For lifetime MDD, the BDI had a sensitivity of 77 percent, specificity of 65 percent using the usual methods, and specificity of 72 percent using their modified method. Although they did not report the time lag between the screening instrument and the diagnostic interview, it is possible that over two months elapsed in many, if not most, cases. This explains why they compared the BDI with lifetime MDD rather than current MDD. Lifetime MDD, unfortunately, is of limited clinical utility in the primary care setting.

Roberts et al., 1991: ^73^ One study examined both the BDI and the CES-D in a stratified random sample of students from five high schools in rural and urban west-central Oregon. Study authors report that approximately 61 percent (n = 1,704) of selected students participated in the study. They did not describe why they only reported an approximate number of participants, and they also did not report the number of youth invited to participate. Our interpretation is that these 1,704 youth completed at least one of the screening instruments and a diagnostic interview using the K-SADS. They did not report whether the interviewers were blinded to the screening results.

The youth in this study were an average of 16.6 years old, 53 percent female, and 91 percent white. Fifty-three percent of the students lived with both of their natural parents and 42 percent of the fathers had completed four or more years of college. The authors did not report the prevalence of depression in their sample. Using a BDI cutoff of 11, they report sensitivity of 83.7 percent, specificity of 80.9 percent, PPV of 10.2 percent, and NPV of 99.5 percent for current MDD. CES-D had similar performance characteristics: sensitivity of 83.7 percent, specificity of 75.2 percent, PPV of 8.0 percent and NPV of 99.4 percent for current MDD using a cutoff of 24. Questions about the sample's characteristics, low participation rate, and potential lack of blinding limit confidence in this study's results.

Garrison et al., 1991: ^74,^ ^75^ The study recruited all 7^th^ graders enrolled in four middle schools in a suburban school district in the southeastern US during 1985. Students joining those four classes during either of the subsequent two years were also recruited. A total of 2,488 students completed the CES-D. A stratified (based on CES-D results) random sample of 332 students completed a diagnostic interview using the K-SADS. Interviewers were blinded to the students' screening scores. The authors did not report the number of students invited to complete the interview. Because of the two-step, stratified sampling procedure, weighted estimates, rather than raw data, were used to calculate instrument accuracy. The time between the CES-D and the diagnostic interview was not reported.

Forty-two percent of the students completing the interview were aged 12 years or younger at baseline, and an additional 38 percent were 13 years old. Fifty-seven percent of the students were female, 75 percent were White, 25 percent were African American, 49 percent lived with both natural parents, and 36 percent of the fathers completed high school but not college. Educational attainment of an additional 35 percent of fathers was unknown. The prevalence of depression in this sample was 8.2 percent in males and 8.7 percent in females, based on the diagnostic interview. This study reported instrument characteristics for males and females separately at four different cutoffs: 12, 16, 20, and 22. The CES-D performed more poorly in boys than in girls at all cutoffs but the lowest, 12. Their highest cutoff of 22 is most comparable to the previous study and demonstrated fairly good performance characteristics in girls: sensitivity was 83 percent, specificity was 77 percent, and PPV was 25 percent for MDD. For boys, however, the CES-D performed poorly at a cutoff of 22, with sensitivity of 18 percent, specificity of 83 percent, and PPV of 9 percent.

Patton et al., 1999: ^76^ The study used a two-stage cluster sampling procedure to first select 45 schools in Victoria, Australia for participation. Two classrooms were then selected from each school. After completing the CIS-R as a screening tool, all those who screened positive and a random sample of those screening negative were invited to complete a diagnostic interview within three weeks using the depression and hypomania modules of the CIDI. Because of the sampling strategy, weighted estimates were used to calculate CIS-R performance characteristics. Eighty-five percent (n = 1,729) of the 2,032 students invited to participate completed the screening instrument, and 170 completed the diagnostic interview.

Study participants had an average age of 15.7 years (SD 0.5), were 53 percent female, and had a 6.2 percent prevalence of current MDD, based on the diagnostic interview. The study reported a very low sensitivity of 18 percent, specificity of 97 percent, PPV of 49 percent, and NPV of 91 percent. The low sensitivity of the study bears further exploration of the psychometric properties of the screening instrument. The CIS-R was originally developed as a tool for lay interviewers to conduct diagnostic interviews. The original research on this instrument examined the consistency of results between two interviewers, but test-retest stability and the performance characteristics of the instrument relative to a gold standard were not reported.^77^ Although the current authors designed and conducted the study fairly well, the instrument may have been flawed in its original form, or adaptation to a self-administered, computer-based format may have been untenable, or both.

## Key Question 3. What are the harms of screening?

### Summary of findings

No studies were found that examined harms of depression screening programs in youth.

### Study details

None.

## Key Question 4. Does treatment of depression (SSRIs and/or psychotherapy) among screen-detected children and adolescents identified in primary care or comparable populations improve health outcomes?

### Summary of findings

We identified 18 fair- or good-quality RCTs that reported health outcomes among children or adolescents with MDD treated with SSRIs and/or psychotherapy (Table 7). These trials evaluated the short-term efficacy of five different SSRIs against placebo control conditions, ten different group or individually-delivered psychotherapies compared with control conditions, and combined therapy including both cognitive-behavioral psychotherapy and an SSRI. Two of these trials were conducted in community- or school-based clinical settings (both good-quality RCTs),^78,^ ^79^ and the remainder were conducted in academic research centers or in schools (e.g., classroom-based). The majority of SSRI trials (6/9) included children at least as young as 8 years old in their study samples. The majority of trials testing psychotherapy interventions included only adolescents 12 to 14 years and older. Only two psychotherapy trials included 9- or 10-year-olds, and no completed trials included children 7 or 8 years of age. In total, nine of the SSRI or psychotherapy trials were good quality, according to USPSTF criteria, and nine were fair quality. Good-quality trials typically used a multigated screening procedure, including a clinical assessment, to identify depressed participants, measured outcomes through blinded clinical assessments (and often also self-reported depression symptoms), and analyzed intention-to-treat populations, most often using LOCF data to replace missing values. Collaborative care interventions were outside the scope of this report, but are addressed in the discussion of our results. Depression outcomes were reported after 8 to 12 weeks of SSRI treatment or 4 to 16 weeks of psychotherapy. No controlled data were available for longer-term outcomes. Additional relevant outcomes were reported regarding global functioning.

Table 7 Characteristics of randomized controlled trials of depression treatment in children and adolescents (KQ 4)

Reference | Intervention | Age range, y | N patients randomized | Length of intervention, weeks | Response Criteria | Response rate | | Risk Difference, % (95% CI) | USPSTF Quality^a^
| | | | | | Treatment Group | Control Group
SSRIs^a^
Emslie, 1997^63,^ ^94^ | IG: Fluoxetine CG: Placebo | 7–17 | 96 | 8 | CGI-I ≤ 2 | 27/48 (56) | 16/48 (33) | 23 (4 to 42) | Fair
Emslie, 2002^88,^ ^94^ | IG: Fluoxetine CG: Placebo | 8–17 | 219 | 9 | ≥ 30% decrease in CDRS-R | 71/109 (65) | 54/101 (54) | 12 (-2 to 25) | Fair
TADS, 2004^78^ | IG1: Fluoxetine CG: Placebo | 12–17 | 221 | 12 | CGI-I ≤ 2 | 66/109 (61) | 39/112 (35) | 26 (13 to 39) | Good
Keller, 2001^80^ | IG: Paroxetine CG: Placebo | 12–18 | 180^a^ | 8 | HAM-D ≤ 8 or ≥ 50% reduction from baseline | 60/90 (67) | 48/87 (55) | 12 (-3 to 26) | Good
Berard, 2006^82^ | IG: Paroxetine CG: Placebo | 13–18 | 286 | 12 | ≥ 50% decrease in MADRS | 107/177 (61) | 53/91 (58) | 2 (-10 to 15) | Good
Emslie, 2006^83^ | IG: Paroxetine CG: Placebo | 7–17 | 206 | 8 | CGI-I ≤ 2 | 49/101 (49) | 46/100 (46) | 3 (-11 to 16) | Good
Wagner, 2003^81,^ ^93^ | IG: Sertraline CG: Placebo | 6–17 | 376 | 10 | ≥ 40% decrease in adjusted CDRS-R | 127/185 (69) | 105/179 (59) | | Good
Wagner, 2004^89^ | IG: Citalopram CG: Placebo | 7–17 | 178 | 8 | CDRS-R score ≤ 28 | 32/89 (36) | 20/85 (24) | 12 (-1 to 26) | Fair
Wagner, 2006^84^ | IG: Escitalopram CG: Placebo | 6–17 | 268 | 8 | CGI-I ≤ 2 | 81/129 (63) | 69/132 (52) | 11 (-1 to 22) | Good
Psychotherapy Interventions
Clarke, 1999^102^ | IG1: Group CBT IG2: Group CBT + Parent CG: Waitlist | 14 – 18 | 123 | 8 | No longer meeting DSM-III-R criteria for 2 weeks based on LIFE clinical interview | IG1: 24/37 (64.9%) IG2: 22/32 (68.8%) | 13/27 (48.1%) | P < 0.05 (IG1 and IG2 combined vs. CG) | Good
Kahn, 1990^105^ | IG1: Group CBT IG2: Group relaxation IG3: Individual self-modeling CG: Waitlist | 10–14 | 68 | 6–8 | Moved from dysfunctional to functional BID score | IG1: 13/17 (76%) IG2: 11/17 (65%) IG3: 10/17 (59%) | 3/17 (18%) | p-values NR | Fair
Lewinsohn, 1990^106^ | IG1: Group CBT IG2: Group CBT + Parent CG: Waitlist | 14–18 | 69 | 7 | No longer meet DSM-III-R criteria based on K-SADS-E | IG1: 42.9% IG2: 47.6% | 5.3% | P < 0.01 (IG1 and IG2 combined vs. CG) | Fair
Stark, 1987^109^ | IG1: Group Self-Control IG2: Group Behavioral Problem Solving CG: Waitlist | 9–12 | 29 | 5 | CDI < 13 | IG1: 7/9 (78%) IG2: 6/10 (60%) | 1/9 (11%) | NR | Fair
Rosello, 1999^108^ | IG1: Individual IPT IG2: Individual CBT CG: Waitlist | 13–17 | 71 | 12 | CDI ≤ 17 | IG1: 82% IG2: 59% | NR | NR | Fair
Mufson, 1999^107^ | IG1: Individual IPT CG: Clinical Monitoring | 12–18 | 48 | 12 | HRSD < 6 CGI-S | 75% 20/21(95.5%) | 46% 7/11 (61.5%) | p = 0.04 p < 0.001 | Fair
Mufson, 2004^79^ | IG1: Individual IPT CG: Treatment as Usual | 12–18 | 64 | 16 | HAMD ≤ 6 | 17/34 (50%) | 10/29 (34%) | p-value NR | Good
Diamond, 2002^103^ | IG1: Attachment-Based Family Therapy CG: Waitlist | 13–17 | 32 | 12 | No longer meet criteria for MDD on K-SADS-P | 13/16 (81%) | 7/15 (47%) | P = 0.04 | Good
Ackerson, 1998^104^ | IG1: Cognitive bibliotherapy CG: Waitlist | 14–18 | 30 | 4 | NR | NR | NR | N/A | Fair
TADS, 2004^78^ | IG2: Individual CBT CG: Placebo + clinical monitoring | 12–17 | 223 | 12 | CGI improvement score of 1 or 2 | 43.2% (95% CI 34 – 52) | 34.8% (95% CI 26 – 44%) | P = 0.20 | Good
Psychotherapy and SSRI
TADS, 2004^78^ | IG3: Individual CBT + fluoxetine CG: Placebo + clinical monitoring | 12–17 | 209 | 12 | CGI improvement score of 1 or 2 | 71% (95% CI 62% – 80%) | 34.8% (95% CI 26 – 44%) | | Good

a USPSTF Quality Criteria are described in Appendix B, Table B3

b Source of SSRI summary data: Bridge et al., 2007

Abbreviations: y-year; N-number; CI-confidence interval; USPSTF-United States Preventive Services Task Force; IG-intervention group; CG-control group; CGI-I-Clinical Global Impression-Improvement scale; CDRS-R-Children's Depression Rating Scale-Revised; HAM-D-Hamilton Rating Scale for Depression; MADRS- Montgomery-Asberg Depression Rating Scale; DSM-III-R-Diagnostic and Statistical Manual of Mental Disorders, 3^rd^ edition, revised; CBT-cognitive-behavioral therapy; LIFE-Longitudinal Interval Followup Evaluation; BID- Bellevue Index of Depression; K-SADS-E- Kiddie-Schedule for Affective Disorders and Schizophrenia-Epidemiological edition; IPT-interpersonal therapy; HRSD-Hamilton Rating Scale for Depression; CGI-S-Clinical Global Impression-Severity of Illness; NR-not reported; K-SADS-P-Kiddie-Schedule for Affective Disorders and Schizophrenia-Present Version

We calculated that for the nine SSRI trials, the pooled absolute risk difference in the response between treatment and intervention groups was 12 percent (95 percent CI 7, 16; random-effects analysis), indicating higher response rates among those treated with SSRIs. When considering individual SSRIs, fluoxetine and citalopram both yielded statistically significant higher response rates. Data from meta-analyses of efficacy among children and adolescents analyzed separately in a recent systematic review by Bridge and colleagues (2007) suggested that overall, SSRIs were less effective among children. When restricting the analysis to only fluoxetine trials, however, results were similar for both children (RD 21 percent, 95 percent CI 4, 37) and adolescents (RD 20 percent, 95 percent CI 7, 33). These results were statistically significant for both groups.

Nine out of the ten psychotherapy trials found that treated patients had higher response rates or a greater reduction in depression symptoms after interventions, compared with a variety of control conditions. Two studies included children aged nine and ten years and both reported that mean clinician-rated depression scores improved more among treated patients than control group patients. No trials included children aged seven or eight years. One trial tested the effect of psychotherapy plus SSRI (TADS trial). Seventy-one percent (95 percent CI 62, 80) of adolescents treated with combination therapy achieved response criteria compared to 34.8 percent (95 percent CI 26, 44) of placebo control patients. This trial did not include any patients younger than 12 years of age.

### Study details - SSRIs

We identified nine good- ^78,^ ^80^–^87^ or fair-quality,^63,^ ^88,^ ^89^ double-blind, placebo-controlled RCTs evaluating the short-term health outcomes of five different types of SSRIs to treat MDD among children or adolescents (randomized total of 2,030 participants). Two separate RCTs evaluating sertraline were pooled and reported in one publication by the study authors and are discussed here as one trial.^81^ Eight of the nine trials were published after the search window of the previous USPSTF report. We found no additional completed unpublished trials. We present the pooled risk difference and 95 percent confidence interval of the response rate to SSRI treatment for the nine trials that met our inclusion and exclusion criteria.

We also identified numerous recent systematic evidence reviews that included both published and unpublished results and examined the efficacy of SSRIs for treating MDD in youth.^65,^ ^66,^ ^90^–^92^ We include results from the most recently published, good-quality systematic evidence review by Bridge and colleagues, which was the only review that included all of the trials that we identified through our searches.^92^ This meta-analysis, however, also includes results from six trials of antidepressants for treating MDD that did not meet our inclusion and exclusion criteria. Two additional publications report post hoc analyses of efficacy by age subgroups.^93,^ ^94^

#### Trial characteristics

Trials evaluated the efficacy of fluoxetine, paroxetine, sertraline, citalopram, and escitalopram. Length of treatment ranged from eight to 12 weeks. Most trials involved multiple sites and were conducted in the United States or Canada in research/academic settings. The TADS trial was the only one conducted predominantly in clinical settings located in the community and was described as an effectiveness trial. Trials included children and adolescents between the ages of 6 to 18 years of age; three exclusively enrolled adolescents.^78,^ ^80,^ ^82^ Approximately half to two-thirds of included participants were females and 18 to 32 percent were racial or ethnic minorities.

All trials required patients to have MDD of at least moderate severity (baseline CDRS-R scores ranging from 55 to 65 points). The average duration of depressive illness at the time of study entry varied from 3 to 26 months. Trials also varied with respect to the prevalence of other psychiatric comorbidities in the study populations. Three trials reported that psychiatric comorbidities were common among the studied population (40 to 50 percent of population).^78,^ ^80,^ ^81^ Four trials excluded patients who had other psychiatric disorders.^81,^ ^84,^ ^89^ Few trials reported including patients with comorbid anxiety disorders (15 to 28 percent prevalence)^78,^ ^80,^ ^82^ or ADHD (12 to 17 percent prevalence).^78,^ ^88^ Trials generally excluded patients who reported a history of substance abuse. One trial did not describe whether patients with substance abuse issues were included.^81^

#### Trial quality

Overall, these trials were of good quality. Most of the trials described an adequate randomization method (e.g., computer-generated sequence). All trials were described as double-blind with the treatment allocation masked from participants and study staff; three reported that study drug and placebo were actually packaged identically to ensure blinding.^81,^ ^82,^ ^84^ The remaining trials did not use any specific language describing how the allocation sequence was concealed from the researchers enrolling participants. Eligibility criteria were well described and appropriate. The characteristics of the baseline populations were also described in detail and indicated that randomization procedures were successful with regard to important potential confounding characteristics. Most of the trials excluded patients who were participating in any other specific psychotherapy, but allowed (or provided) some type of supportive psychotherapy. Attrition ranged from 18 to 38 percent and was similar between groups, except for two fair-quality trials in which attrition was higher in the control groups (38 to 46 percent) than the intervention groups (17 to 29 percent).^63,^ ^88^ Most trials did not report how well patients adhered to taking study medications, except reporting those who discontinued completely. All trials conducted analyses on the intention-to-treat population, although most excluded patients who did not take at least one dose of study drug or placebo and complete at least one subsequent outcome assessment. In general, trials used the last observation carried forward method; some used either linear coefficient regression or rate of change methods to predict missing outcomes.

#### Outcomes

The definition of treatment response varied across trials. Trials reported binary response rates as well as changes in continuous scores over time between groups. Most trials defined the primary measurement of response to treatment using either the Clinical Global Inventory-Improvement scale^95^ or a predefined level of change in the Children's Depression Rating Scale-Revised score.^96^ The CDRS-R was the most common continuous depression scale used to report the mean change in symptoms over time. Outcomes were measured at post-treatment, which ranged from 8 to 12 weeks. Remission was defined as CDRS-R score of 28 or less, but was reported in only three trials.

#### Results

Response rates among treatment and placebo groups varied across all nine trials (Table 7). Thirty-six to 69 percent of patients in treatment groups met response criteria at post-intervention followup compared to 24 to 59 percent of patients in placebo control groups. Considering individual trials, the absolute risk differences were highest among two trials of fluoxetine in which 56 to 61 percent of fluoxetine-treated patients met response criteria at 8 to12 weeks, in contrast with only 33 to 35 percent of placebo-treated patients. Notably, approximately 40 percent of patients treated with fluoxetine did not meet response criteria. These trials were also the only two in which differences in response rates between intervention and control group were statistically significant. The two trials in which the risk differences were lowest (2 to 3 percent) were both trials of paroxetine. Based on the outcomes reported in all nine RCTs (1,972 participants), the pooled absolute risk difference was 12 percent (95 percent CI 7, 16) (Figure 2; random effects model). These results indicate that a greater proportion of patients treated with an SSRI responded compared to patients treated with placebo.

Figure 2. Response to SSRIs to treat MDD in RCTs including children and adolescents

Remission rates were reported for three of the trials.^83,^ ^85,^ ^88^ Emslie and colleagues (2002) reported that 41.3 percent of patients in the fluoxetine treatment group met remission criteria compared to 19.8 percent of patients in the placebo control group (p < 0.01). Kennard and colleagues (2006) reported that among adolescents in the TADS trial, remission rates were similar between fluoxetine- and placebo-treated groups (23 percent vs. 17 percent, ns). Emslie and colleagues (2006) reported finding no difference in remission rates between paroxetine- and placebo-treated children and adolescents (results combined across age groups).

Mayes and colleagues analyzed the efficacy of fluoxetine for children (< 12 years; n = 134) compared to adolescents (≥ 12 years; n = 175), ^94^ using data from two of the published RCTs of fluoxetine.^63,^ ^88^ In a random regression analysis of the CDRS-R score, they reported a significant treatment group by age group interaction (p = 0.044). Reductions in CDRS-R scores from baseline were significantly greater for those treated with fluoxetine versus placebo in both children (p<.001) and adolescents (p = .011). The effect sizes indicated that the treatment effect was larger among children (ES 0.71) than adolescents (ES 0.39). They reported that among children, response rates to fluoxetine were significantly better than placebo (56.9 percent vs. 33.3 percent; p = 0.009). Among adolescents, response rates were also higher to fluoxetine than placebo (51.1 percent vs. 38.6 percent) but were not statistically significant (p = 0.128). Data from one other trial of fluoxetine in adolescents with MDD (TADS trial) were not included in these analyses.

Donnelly and colleagues analyzed the efficacy of sertraline by age group,^93^ using data from a previously published trial^81^ that included 177 children and 199 adolescents. Among adolescents, mean change in CDRS-R scores favored sertraline treated patients over placebo (p = 0.012). In contrast, mean change in CDRS-R scores were not different between sertraline and placebo-treated children.

Bridge et al., 2007: ^92^ Bridge and colleagues recently published a good-quality systematic evidence review in which they conducted meta-analyses of efficacy and adverse effects for all antidepressants (including non-SSRI atypical antidepressants) to treat MDD, obsessive-compulsive disorder, or non-obsessive-compulsive anxiety disorders in children or adolescents. They present results separately for MDD trials and also calculated pooled outcomes for children and adolescents separately. In addition, they evaluated trial-level variables as potential moderators of outcome effects. Bridge and colleagues quality rated individual trials using Detsky scores, but did not exclude trials based on quality considerations. The review includes 15 MDD trials that randomized 3,430 participants overall. It included the nine RCTs that met our inclusion and exclusion criteria, two RCTs that we excluded due to poor quality (a fluoxetine trial^62^ and a citalopram trial^97^), and four additional trials evaluating atypical antidepressants. Based on data from 2,910 participants in 13 RCTs, they found that the pooled absolute rates of response were 61 percent (95 percent CI 58, 63) among participants treated with antidepressants and 50 percent (95 percent CI 47, 53) among participants treated with placebo, which yielded a pooled risk difference of 11 percent (95 percent CI 7, 15), and a number needed to treat (NNT) of 10 (95 percent CI 7, 15). These results were based on a random-effects model, which assumes that heterogeneity across trials is not fully accounted for by the observed covariates and provides a more conservative estimate of effect than a fixed-effect model because it incorporates within- and between-study heterogeneity. The authors also conducted pooled analyses of the continuous measures of mean improvement in depression symptom scores and found that those results demonstrated a consistent effect of greater response among treated participants compared to control groups (Hedges g = 0.20; 95 percent CI 0.12, 0.29). The Hedges g for individual trials ranged from -0.06 to 0.60. The Hedges g was statistically significant (the 95 percent confidence interval did not cross zero) for the results of five individual trials and ranged from 0.28 to 0.60 across those trials.^63,^ ^78,^ ^81,^ ^88,^ ^89^

Results of the pooled RD and NNT, stratified by type of SSRI, are presented in Table 8. The pooled RD was largest for the fluoxetine trials (RD 20, 95 percent CI 11, 29), and the NNT was 6 (4 to 10), indicating that an estimated six patients with MDD would need to be treated in order for one to benefit. Results of the data from citalopram and escitalopram were also statistically significant (RD 8 percent, 95 percent CI 1, 16), and the NNT was 13 (7 to 200). Results from trials testing these two drugs were pooled because escitalopram is the active component of citalopram. We excluded one trial of citalopram due to poor quality.^97^ To understand this trial's impact on the pooled results among the citalopram and escitalopram trials, we recalculated the pooled RD for the citalopram trial^89^ and the escitalopram trial^84^ that met our inclusion criteria; the results remained statistically significant (RD 11 percent, 95 percent CI 2, 20).

Table 8 Pooled estimates of efficacy outcomes in randomized controlled trials of SSRIs in Major Depressive Disorder among children and adolescents^92^

| Response Rate^a^ No. Response/Total (%) | | Risk Difference, % (95% CI) | NNT (95% CI)
Treatment | Placebo
Fluoxetine | 164/266 (62) | 109/261 (42) | 20 (11 to 29) | 6 (4 to 10)
Paroxetine | 216/368 (59) | 147/278 (53) | 5 (-3 to 13) | ...
Sertraline | 127/185 (69) | 105/179 (59) | 10 (0 to 20) | 10 (6 to 500)
Citalopram/Escitalopram | 163/301 (54) | 136/294 (46) | 8 (1 to 16) | 13 (7 to 200)

a Criteria for response to treatment varied across individual trials

SSRI-selective serotonin reuptake inhibitor; No.-number; NNT-number needed to treat; CI-confidence interval

Bridge and colleagues conducted numerous secondary analyses to explore the effects of potential moderating variables. They explored the role of continuous moderators (methodological quality, number of treatment sites, proportion of female participants, duration of illness at baseline) using regression analyses. Continuous variables that were associated with outcome were dichotomized by median split and analyzed as categorical variables. They also evaluated the role of trial-level categorical variables that could have had a moderating effect (publication status, primary funding source, study location, drug class, use of placebo run-in period). They assessed for publication bias visually using a funnel plot and quantitatively using an adjusted rank correlation test and a regression procedure to measure funnel plot asymmetry. They found that the number of trial sites and the duration of the MDD episode at intake to the study were both inversely associated with the risk difference in response and the scalar measure of efficacy. These results indicate that study drugs were less efficacious in trials with more study sites or that included patients who, on average, had had MDD for longer periods prior to the start of the trial. Study quality and proportion of females were not associated with the efficacy outcomes.

Age-grouped data were available for 10 of the 15 included MDD trials. The authors found that the pooled risk difference in response was lower among children than among adolescents and not statistically different than zero. Children generally had a higher placebo response. When restricting to the fluoxetine trials only, however, the pooled RDs were similar for children (RD 21 percent, 95 percent CI 4, 37) and adolescents (RD 20 percent, 95 percent CI 7, 33). Other categorical trial-level variables (drug class, publication status, and placebo run-in period) were not significant. They did not evaluate the role of funding agency because the only two trials funded by the National Institutes of Mental Health were evaluating fluoxetine.^63,^ ^78^ All other trials were funded by the drug industry.

### Study details - psychotherapy intervention

Numerous systematic evidence reviews and meta-analyses focusing on the efficacy of psychotherapy for treating depression in youth have been published since the end of the previous USPSTF review's search window. The inclusion and exclusion criteria used in these reviews, however, only partially overlapped with our criteria. We used the five most recently published SERs as supplemental sources for identifying trials relevant for this report.^91,^ ^98^–^101^ In total, we located ten good-^78,^ ^79,^ ^102,^ ^103^ or fair-quality^104^–^109^ RCTs evaluating psychotherapeutic interventions to treat children or adolescents with depression that met our inclusion and exclusion criteria. These trials randomized a total of 757 patients who ranged in age from 9 to 18 years old and included 16 different comparisons of depression outcomes between an intervention and control condition. A variety of group and individual therapies were tested. Group CBT, individual IPT-A, and individual CBT were the only interventions tested in multiple trials. Two studies were effectiveness trials (both good quality) conducted in actual community clinical settings (one of IPT-A and one of individual CBT). Other interventions were tested for efficacy in schools or research settings that were not specifically described.

Seven trials reported response to treatment based on clinician-rated measures.^78,^ ^79,^ ^102,^ ^103,^ ^105^–^107^ These trials used a variety of different criteria to define response criteria, such as no longer meeting DSM-III-R criteria for depression based on a diagnostic interview,^102,^ ^103,^ ^105,^ ^106^ or a change in Hamilton Rating Scale for Depression^79,^ ^105,^ ^107^ or CGI-S score.^78,^ ^105,^ ^107^ Of the three trials which didn't report response criteria based on clinician-rated measures, two reported the mean change in a clinician-rated measure,^104,^ ^109^ and one trial only measured outcomes using self-reported measures.^108^ Trials reported outcomes at post-intervention assessments at 5 to 16 weeks post-randomization. Only one trial reported usable followup data with controlled comparison observations.^109^ One other trial that reported a controlled followup comparison had markedly differential attrition at 8-week followup.^105^ These results are not included in this report. Four other trials measured outcomes at followup assessments, but waitlist control groups started (or completed) treatment, therefore the effect of the intervention could not be differentiated from the effect of time at the followup assessment. Four trials did not report followup data.^78,^ ^79,^ ^103,^ ^107^

Nine of ten trials reported a statistically positive difference indicating a higher response (either response rate or mean depression score) for the intervention group compared to the control group. Five trials reported that response rate was higher in the intervention group than control group. These statistically significant results were based on clinician-rated measures (four trials)^102,^ ^103,^ ^106,^ ^107^ or self-reported measures.^79^ Three others reported that mean values of depression scores were lower among intervention group participants compared to control group. These statistically significant results were also based on clinician-rated^104,^ ^105,^ ^109^ or self-reported measures.^108^ The only trial that reported no statistically significant difference between the intervention group and control group was the TADS trial. In that particular trial, however, the control group consisted of daily placebo pills and bi-weekly meetings with a clinician (20 to 30 minutes each) to monitor symptoms and deliver encouragement that the placebo pill would be effective. Since this control condition was serving as control for fluoxetine interventions as well, it is unclear if the clinical monitoring could have improved depression symptoms.

Only two studies included children younger than 9 or 10 years of age, and both showed evidence that the interventions were efficacious.^105,^ ^109^ These fair-quality trials randomized a total of 97 patients. While the absolute differences between the response rates in the intervention and control groups were quite high (41 to 67 percent; data not shown), p-values were not reported for response rates in either trial. Results from mean depression scores indicated that clinician-rated symptoms improved more in the intervention groups than control groups and were statistically significant. No trials included children 7 or 8 years old.

#### Primary Care Settings

Mufson et al., 2004: ^79^ This good-quality RCT (n = 64) measured the effectiveness of individual Interpersonal Therapy for Adolescents (IPT-A) delivered by clinicians in school-based health clinics. The study was set in impoverished areas of New York City. The population was predominantly Hispanic females. The intervention was delivered by school health clinicians (social workers and doctoral-level clinical psychologists) who received trial-specific training. Eligible patients were referred for treatment to the school health clinic and had to meet DSM-IV criteria for MDD, DD, adjustment disorder with depressed mood, or depressive disorder NOS. Patients were randomized to IPT-A for 16 weeks or treatment as usual (TAU) control. TAU was whatever care the students would have received in the school health clinic if the study hadn't been taking place. Most received individual psychotherapy, eight received family therapy, and five participated in group therapy. Recovery criteria for the trial were defined as HAMD ≤ 6 or BDI ≤ 9.

At post-intervention (week 12), a greater proportion of patients in the IPT-A group met HAM-D recovery criteria compared to the TAU group, although the difference was not statistically significant (50 vs. 34 percent, p-value NR). The recovery rate based on the BDI score was also higher among the IPT-A group compared to TAU (74 vs. 52 percent, p = 0.048). Mean clinician-rated depression scores (HAMD) showed greater improvement for the IPT-A group compared to TAU at post-treatment (p = 0.04; ES 0.50). The difference in HAMD scores between groups emerged at week 8, with a 4.1 point difference (p = 0.003). Random regression analysis indicated that the IPT-A group recovered at a significantly faster rate than the CG. Differences in BDI scores also emerged between the groups at week 8, favoring the IPT-A group by 5.42 points (p = 0.001). Two measures of global functioning also indicated statistically significant differences between groups, favoring the IPT-A group. Attrition was 11 percent, and the ITT population was analyzed using the LOCF method. Generalizability, however, is limited because of the predominantly low SES, Hispanic population.

TADS, 2004: ^78^ TADS is a good-quality RCT (n = 439) in which adolescent subjects ages 12 to 17 years with MDD were randomized to four different conditions, including individual CBT and a placebo control condition (n = 223 for these two groups). The patients were a volunteer sample recruited from clinical, community, and school settings and 13 different academic and community sites in the USA. The individual CBT condition involved 15 1-hour sessions over 12 weeks. The control condition for the CBT arm of the trial was designed to also serve as the control for the arms receiving fluoxetine alone or with CBT. Patients in this control group were treated with placebo pills. The patients had 6 20- to 30-minute visits with a physician to monitor clinical status and medication effects (of the placebo), adjust the dose of the placebo, and to offer general encouragement about the effectiveness of pharmacotherapies. Patients and all study personnel were blinded to whether or not the pill was the study drug or not.

The primary depression outcome, response rate as measured by the CGI-I score, indicated no statistically significant difference between the CBT group and the placebo control group (43.2 vs. 34.8 percent, p = 0.20). CDRS and RADS scores also showed no difference. Suicide- and harms-related adverse events were also not different between groups. This good-quality trial included patients similar to those seen in primary care settings. The control condition, however, was not an ideal comparison to the intervention. The clinical monitoring could have improved depression symptoms, even though they were of lower intensity than the CBT. A placebo effect could have also increased response in the control group.

#### Research Clinic Settings

Clarke et al., 1999: ^102^ This good-quality RCT (n = 123) evaluated group CBT for adolescents and group CBT with separate parent sessions. Patients aged 14 to 18 years were recruited by health professionals, school counselors, and advertisements and were screened by diagnostic interview. Patients were required to meet DSM-III-R criteria for MDD or dysthymia to be eligible. Patients were randomized to two intervention groups or a control group. The group CBT intervention condition (adolescent-only) followed the Adolescent Coping with Depression Course, including 16 two-hour sessions delivered over eight weeks (mean attendance was 14 of 16 sessions). In the second intervention group (adolescent + parent), adolescents participated in the same group CBT course and their parents participated in eight weekly parent sessions. Nearly 90 percent of adolescents in the adolescent + parent group had at least one of their parents attend the sessions, with greater attendance by mothers than by fathers. The control group was a wait-list condition in which participants were offered treatment after the experiment.

After eight weeks, patients were assessed by blinded clinicians. Self- and parent-reported measures were also assessed. Recovery was defined as no longer meeting DSM-III-R criteria for either major depression or dysthymia for the two weeks preceding the post-treatment assessment. Recovery rates were higher in both the adolescent-only group (24/37, 64.9 percent) and the adolescent + parent group (22/32, 68.8 percent), compared to the waitlist control group (13/27, 48.1 percent). The results of the two intervention groups were combined and compared to the control group for statistical analyses, which yielded significant results (chi-squared, p < 0.05; Cohen's h = 0.38 - small to medium effect). The odds ratio for estimating the relative risk of recovery was 2.15 (95 percent CI 1.01, 4.59). Differences in clinician-rated HAM-D scores were not significant between intervention groups and the control group. Clinician-rated global assessment of function (GAF) scores were higher in the intervention groups compared to the control group (p < 0.05, change score effect size = 0.54). Attrition was 22 percent overall and outcomes were analyzed using intention-to-treat analyses using random effects regression to predict outcomes for subjects with missing data based on all available data.

Diamond et al., 2002: ^103^ This was a small, good-quality RCT (n = 32) conducted in a low socioeconomic, predominantly African-American sample of adolescents aged 13 to 17 years old. Patients with a primary diagnosis of MDD meeting DSM-III-R criteria were randomized to an Attachment Based Family Therapy (ABFT) intervention for 12 weeks or to a wait-list condition for 6 weeks. Outcomes at the post-intervention assessment at 12 weeks were compared to the post-waitlist assessment for the control condition at 6 weeks (a 12-week waitlist condition was considered to be unethical). Selected outcomes were also compared using the mid-intervention (6 weeks) assessment results for the ABFT group in order to compare groups at an equivalent time point. Clinically significant response was defined as a self-reported BDI score ≤ 9. Depression severity was also assessed by clinician-rated HAM-D scores by blinded interviewers.

For comparisons between ABFT at post-intervention (12 weeks) and control group at post-waitlist (6 weeks), the ABFT group had a higher clinically significant response rate (62 vs. 19 percent, p = 0.01), and greater proportion no longer meeting criteria for MDD (81 vs. 47 percent, p = 0.04). The ABFT group also had a higher proportion with clinically significant reduction in symptoms when comparing outcomes measured at 6 weeks for both groups (56 vs. 19 percent (p = 0.03). Clinician-rated depression scores (HAM-D) and self-reported anxiety scores (STAIC) were also lower for the post-intervention ABFT group compared to CG (p = 0.005, effect size 1.21), but self-reported depression scores (BDI) were not statistically significant. Suicidal ideation and levels of hopelessness were reduced in the ABFT group compared to control group, but did not reach statistical significance (p = 0.09; ES 0.52 and p = 0.08; ES 0.78). No attrition occurred in this trial.

Mufson et al., 1999: ^107^ This fair-quality RCT (n = 48) evaluated the efficacy of 12 weeks of individual Interpersonal Psychotherapy for Depressed Adolescents (IPT-A) among adolescents aged 12 to 18 years who met DSM-III-R criteria for MDD. Patients in the study sample were predominantly Latino and of low socioeconomic status. Patients were recruited from two specialty mental health clinics to which they had mostly been self-referred by parents or mental health professionals in school-based mental health clinics. The control condition consisted of clinical monitoring (CM) on a monthly basis and therapist availability. Therapists were told to refrain from advice giving or skills training and mainly go over symptoms and listen supportively. This condition was used to create an ethical waitlist condition.

Recovery rates based on HRSD ≤ 6 indicated that more IPT-A group patients recovered compared to the CM control group (75 vs. 46 percent, p = 0.04). Results of the Clinical Global Impressions Severity rating demonstrated similar results with a higher proportion rated as improved in the IPT-A group (95.5 vs. 61.5 percent, p < 0.001). Depression scores, as measured by HRSD, BDI, and CGI-S, decreased more in the IPT-A group than in the control condition (p = 0.02, p = 0.05, p < 0.001). No statistically significant differences were present in CGAS scores or suicidality at post-intervention measures. This trial's ITT population was analyzed using the LOCF method to replace missing values and was otherwise similar in quality to those we rated as good quality. Attrition, however, was high overall (33 percent) and was differential between groups (12 percent in IPT-A group and 54 percent in CM control group). It is therefore unclear if groups remained comparable at post-intervention assessment and so the study was rated as fair quality. Generalizability is limited because the population was predominantly low income, Hispanic, and female. In addition, the sample included severely depressed individuals (50 percent with current suicidal ideation at initial assessment) and may not represent the spectrum of disease severity typical of primary care samples.

Rossello and Bernal, 1999: ^108^ This fair-quality RCT (n = 71) set in Puerto Rico evaluated the short-term efficacy of individual IPT (n = 19) and individual CBT (n = 21) compared to a waitlist control group (n = 18). Patients randomized to the IPT or CBT arm of the trial received 12 weekly, 1-hour sessions with a trained therapist. The trial included patients aged 13 to 17 years who were referred to the clinic by local schools and met DSM-III-R criteria for MDD. The study population was 100 percent Latino and 54 percent female. Patients were not eligible if they were receiving any psychotropic medication or psychotherapy at the time of enrollment. At baseline, the three groups were similar on all outcome measures. Baseline demographic characteristics across groups, however, were not reported. Depression outcomes were based on self-reported measures, including the CDI. Adherence was fair, with 68 percent in the IPT arm and 52 percent in the CBT arm completing at least 8 of the 12 sessions. Pre- to post-treatment comparison of CDI scores showed that adolescents in the IPT (F = 11.62, p < 0.002) and CBT (F = 2.58, p < 0.015) groups had significantly lower depressive symptoms compared to those in the waitlist control group. In addition, moderate effect sizes were found for both IPT (0.73) and CBT (0.43). Using a cutoff of 17 on the CDI to separate functional from nonfunctional adolescents, 82 percent of adolescents in IPT and 59 percent of those in CBT showed a clinically significant change.

Ackerson et al., 1998: ^104^ This small, fair-quality RCT (n = 30) evaluated a directed self-help bibliotherapy intervention using Burns' book Feeling Good. Patients were aged 14 to 18 years and recruited through mental health, social service agencies, schools, and other community and clinical settings. Included patients were experiencing mild to moderate depressive symptomatology, as measured by a CDI score of ≥ 10 and an HRSD score of ≥ 10. The sample was 64 percent female and 36 percent nonwhite. Patients were ineligible if they were receiving other forms of psychotherapy, and no patients were being treated with SSRIs. Intervention subjects (n = 12) had 4 weeks to read the Feeling Good book and complete exercises in an accompanying workbook. Subjects were called weekly to collect data on pages read and exercises completed. No counseling was provided during these calls. The control group was a waitlist condition (n = 10). While these patients were also telephoned weekly, the authors do not report any data regarding the content of these calls or whether measures were taken to ensure no counseling occurred.

We rated the quality of this study as fair based on a number of issues. Outcome assessment was not blinded, and neither the details about the contents of the book nor the number of pages read by each participant were reported. Also, while attrition was 27 percent overall (20 percent in the intervention group and 33 percent in the control group), the reasons for dropouts were not provided. The efficacy of bibliotherapy in reducing depression severity was assessed using repeated measures ANOVAs for each outcome measure, comparing pre- and post-treatment scores for the immediate treatment and waitlist conditions. Results indicated that those in the immediate treatment condition had greater improvement in depression severity compared to the waitlist group, as measured by the HRSD (F = 37.78, p < 0.05), self-reported CDI (F = 24.40, p < 0.05), and parent-reported CBCL-D (F = 4.98, p < 0.05). One-month followup data for the immediate treatment condition showed no significant differences in CDI or CBCL-D scores between post-treatment and followup, indicating maintenance of positive treatment effects. HRSD scores were significantly lower at one-month followup compared to immediately after treatment (F = 5.79, p < 0.05), suggesting that some improvement in depressive symptoms continued beyond treatment end. Clinically-significant change was assessed for all 22 subjects who completed treatment (12 immediate treatment and 10 delayed treatment subjects), but was not reported separately by group. Using a cutoff score of <10 on the HRSD and a standardized measure of change greater than 1.96 to indicate clinically-significant change, 59 percent of the completers achieved remission. Using the same cutoffs for the CDI, 64 percent achieved remission.

#### School-based settings

Kahn et al., 1990: ^105^ This fair-quality RCT (N = 68) evaluated the efficacy of short-term group CBT, group relaxation training, or individual self-modeling compared to a waitlist control condition. Patients were latency age adolescents (ages 10 to 14) with moderate to severe depression and were identified by a multistage screening procedure of an entire middle school in a middle-SES neighborhood. Treatments were conducted in schools. Group CBT and relaxation were conducted in small groups of two to five students. These groups consisted of 12 50-minute sessions over a 6- to 8-week period. Post-treatment assessments were conducted by clinicians, approximately half (44 percent) of whom were blinded to the condition. The Group CBT was based on the Adolescent Coping with Depression Course. The self-modeling treatment involved repeated observation of oneself on edited or rehearsed videotape showing only desired target behaviors (e.g., smiling, verbalizing positive self-attributions). Post-intervention scores on the RADS and CDI were both significant for interaction effects between treatment and time (p < 0.001 for both). Pretreatment values were not different. At post-test assessment, a greater proportion of patients in each of the three intervention conditions moved from dysfunction to functional range on depression score measures. Using the RADS scores, 12 percent of CG participants moved to functional at post-treatment versus 88 percent, 65 percent, and 70 percent of CBT, relaxation, or self-modeling, respectively. Attrition was only three percent at post-treatment. At 8-week followup, however, attrition was quite different between groups (44 percent in CG vs. 10 to 11 percent in IGs). Therefore, we cannot be certain of whether the intervention groups differed from the CG in terms of possible confounding variables at the 8-week followup. Also, this study's results were compromised by the fact that only half of the clinicians assessing outcomes were blinded to treatment condition.

Stark et al., 1987: ^109^ This small, fair-quality RCT (n = 29) evaluated group self-control (SC) therapy (n = 9) and group behavioral problem-solving (BPS) therapy (n = 10) compared to a wait-list control condition (n = 9). Participants in the two intervention groups attended 12 45-to 50-minute sessions over 5 weeks. Material from missed sessions was covered individually by therapists. Patients aged 9 to 12 years were identified through a staged screening process at one middle school. Included patients had a CDI score of greater than 16 at first assessment and a CDI score of at least 13 at the second assessment. The population was 43 percent female, and race and ethnicity were not reported. Data regarding the percentage of participants in each group who received other treatment outside of the trial was not specifically reported, but two of the nine subjects on the waitlist were referred to the school psychologist by their teachers for behavior related to depression. These students met with the psychologist weekly. The outcome assessor was blind to treatment assignment.

Within-group comparisons showed that subjects in both the SC group and the BPS group scored significantly lower on the CDI (SC: mean difference = 13.56, SD = 7.76, t = 5.24, p < 0.001; BPS: MD = 12.80, SD = 9.68, t = 4.18, p < 0.01), the CDS (SC: MD = 19.89, SD = 10.94, t = 5.46, p < 0.001; BPS: MD = 15.10, SD = 12.45, t = 3.84, p < 0.01), and the CDRS-R (SC: MD = 13.22, SD = 7.89, t = 5.03, p < 0.001; BPS: MD = 9.40, SD = 9.32, t = 3.19, p < 0.05) at post-treatment compared to pre-treatment scores. The mean difference in pre-post treatment scores for the waitlist control group was not significant for the CDI or CDRS-R, but was significantly lower for the CDS (MD = 8.00, SD = 5.75, t = 4.18, p < 0.01). Results of an ANCOVA controlling for pretreatment scores showed significant differences between the three groups on the CDI (p < 0.01), and differences on the CDS (p < 0.07) and CDRS-R (p < 0.11) approached significance. Using the Bryant-Paulson generalization of Tukey's HSD procedure, the mean post-treatment CDI score was significantly lower in the SC group than the waitlist control group (Q = 4.55, p < 0.05). In addition, change in depression severity was clinically significant. While all subjects scored over 13 on the CDI before treatment, 78 percent in the self-control condition, 60 percent in the behavioral problem-solving condition, and 11 percent in the waitlist condition scored below 13 on the CDI after treatment. Parent ratings on the depression, social withdrawal, and internalizing subscales of the CBCL showed no significant differences between groups at post-treatment. Eighty-two percent of subjects completed followup assessments 8 weeks after the end of treatment. Depression severity in both intervention groups was significantly lower on the CDI (SC: MD = 15.63, SD = 6.50, t = 6.80, p < 0.001; BPS: MD = 14.78, SD = 7.95, t = 5.58, p < 0.001), CDS (SC: MD = 24.25, SD = 13.38, t = 5.13, p < 0.001; BPS: MD = 20.44, SD = 13.67, t = 4.49, p < 0.01), and CDRS-R (SC: MD = 15.38, SD = 6.46, t = 6.73, p < 0.001; BPS: MD = 9.44, SD = 8.10, t = 3.50, p < 0.01) at followup, compared to pre-treatment scores. In addition, SC participants showed significant improvement in CDI (MD = 4.13, SD = 3.48, t = 3.35, p < 0.01) and CDRS-R (MD = 3.00, SD = 3.55, t = 2.39, p < 0.05) scores from post-treatment to 8-week followup, and BPS participants showed significant improvement in CDS scores (MD = 5.44, SD = 6.56, t = 2.49, p < 0.05). Eighty-eight percent of the SC participants and 67 percent of the BPS participants maintained a score below 13 on the CDI at 8-week followup.

Lewinsohn et al., 1990: ^106^ This fair-quality RCT tested the short-term efficacy of two different types of group CBT among adolescents aged 15 to 18 years meeting DSM-III criteria for MDD or RDC criteria for intermittent depression or minor depression (n = 69). Participants were recruited via letters and announcements to health professionals, school counselors, and the media. The sample was 61 percent female. The two intervention conditions were group CBT for the adolescent alone, based on the CWD course (n = 21), and group CBT for the adolescent plus additional separate sessions for the parents (n = 19). The control condition was a waitlist group (n = 19). Adolescents in both intervention groups attended 14 2-hour group CBT sessions twice a week for 7 weeks. Parents in the second intervention group attended 7 2-hour sessions once a week for 7 weeks. Adolescents were interviewed using the K-SADS-E to determine clinical diagnostic status. Only 20 percent of the interviews were dual rated by a blinded interviewer. Quality issues for this trial include lack of information about allocation concealment, blinding of outcomes assessors, and participant adherence to treatment.

At post-treatment, 52.4 percent of the adolescent-and-parent group and 57.1 percent of the adolescent-only group still met diagnostic criteria, whereas 94.7 percent of the control condition still met diagnostic criteria (p < 0.01), indicating greater improvement in the two group CBT intervention conditions. Depression severity was measured by the BDI and the CES-D. Comparison of post-treatment scores for both intervention groups combined, versus the waitlist group, showed significantly lower adolescent depression scores for the treatment groups (BDI: F = 4.27, p < 0.001; CES-D: F = 4.85, p < 0.001). Differences in post-treatment BDI and CES-D scores between the two treatment conditions were not statistically significant. Comparison data from post-treatment, 1-month followup, and 6-month followup was available for 16 participants in the adolescent-only group and 14 participants in the adolescent-and-parent group. There were no significant differences in CES-D or BDI scores between these three time points for either intervention group. Improvements in depression symptoms, therefore, were maintained over a 6-month period.

### Study Details - SSRI + psychotherapy interventions

TADS, 2004: ^78^ TADS is a good-quality RCT (n = 439) of adolescent subjects aged 12 to 17 years with MDD. This study is also described in the sections regarding SSRI or psychotherapy efficacy (monotherapies). In this same trial, some patients were randomized to a condition in which they received fluoxetine and individual CBT (n = 107) and were compared to the placebo control group (n = 112). The fluoxetine therapy allocation was known to the patient and CBT therapist and was meant to more closely resemble the patient-therapist relationship in a naturalistic setting, thus theoretically making results more generalizable. Outcomes were still assessed by blinded clinicians. The patients were a volunteer sample recruited from 13 different academic and community sites in the US. The group CBT condition involved 15 1-hour sessions over 12 weeks, and the fluoxetine was administered at 10 to 40 mg/day for 12 weeks. Patients in the control group were treated with placebo pills. Patients in both the CBT + fluoxetine group and the placebo control group had six 20- to 30-minute visits with a physician to monitor clinical status and medication effects, adjust the dose of fluoxetine or placebo, and offer general encouragement about the effectiveness of pharmacotherapies.

The primary depression outcome was response rate as measured by the CGI-I score, which indicated a higher proportion of patients receiving combined CBT + fluoxetine treatment improved compared to patients treated with the placebo control. Rates of response were 71.0 percent (95 percent CI 62, 80) for CBT + fluoxetine and 34.8 percent (95 percent CI 26, 44) for placebo (p = 0.001). Changes in CDRS-R and RADS scores over the 12 weeks of treatment also showed that CBT + fluoxetine was superior to placebo (p = 0.001). The effect size (Hedges g) on the CDRS-R for CBT + fluoxetine was 0.98, and on the CGI-I it was 0.84. The NNT on the CGI-I was 3 (95 percent CI 2, 4). Decrease in suicidal thinking over the 12 weeks of treatment, measured by the adjusted mean on the Suicidal Ideation Questionnaire-Junior High School Version (SIQ-Jr), was significantly greater in the CBT + fluoxetine group compared to placebo (p = 0.02).

## Key Question 5. What are the adverse effects of treatment?

### Summary of findings

Data describing the adverse effects of SSRIs were available from the nine RCTs included for KQ4 for which we calculated pooled absolute risk differences for suicide-related adverse events (SRE) using data for a subset of trials included in the Bridge 2007 review.^92^ SRE includes suicidal ideation (i.e., passive thoughts about wanting to be dead or active thoughts about killing oneself, not accompanied by preparatory behavior), suicide attempts, or preparatory actions toward imminent suicidal behavior (e.g., a person tries to hang themselves but is prevented from doing so by a family member). In addition, data were available from four meta-analyses that calculated the pooled relative risk or risk difference of suicide-related adverse events based on outcomes assessed using blinded suicidology experts,^92,^ ^110,^ ^111^ or included other serious adverse events (SAE) in addition to SRE.^66^ In addition, data from large retrospective cohort or case-control studies provided observational data describing risk of suicidality, suicide death, and manic conversion. Previous systematic reviews and meta-analyses did not exclude trials based on quality criteria and some did not report any quality rating procedure or results. In contrast, we were able to review published results from all currently completed trials and analyze them in detail using our typical USPSTF quality rating criteria. Bridge and colleagues conducted sensitivity analyses and determined that quality score did not alter the magnitude of their estimates of pooled risk difference. Previous reviews have also used varying inclusion and exclusion criteria (e.g., MDD trials only, SSRIs only) and have used both fixed-effects and random-effects approaches to meta-analyses, as well as Bayesian methods of meta-analyses. The random-effects and Bayesian approaches assume additional sources of trial-related variation across studies and typically produce relative risk estimates that are smaller in magnitude and wider in confidence interval. The FDA researchers used fixed-effects methods, validated by results of heterogeneity tests, to calculate the more conservative estimate. Meta-analyses also differed in terms of calculating RR or RD. The FDA analysis focused on RR and therefore could not include data from four trials (non-SSRI MDD trials) that did not include SAE outcomes in either group.

Most conservative estimates indicate that treating any pediatric population with antidepressants for any indication doubles the relative risk of SAE (RR 1.95, 95 percent CI 1.28, 2.98).^110^ The absolute risk difference between intervention and control populations was one percent (95 percent CI 1, 2). No other meta-analyses reported the pooled RD among SSRI trials for MDD and considered data from all currently available completed trials, including a recently published trial of escitalopram. We calculated the pooled RD of those trials, excluding two poor-quality RCTs, and found an RD of 1 percent (95 percent CI 0, 2). In total, even the most conservative estimates indicate that the risk of suicidality may increase absolutely by one or two percent.

The evidence linking antidepressants and suicidal behavior from two cohort studies (one good quality^112^ and one fair quality^113^) contradicted the results of a good-quality case-control study.^114^ The two cohort studies did not find a relationship between antidepressant use and suicide deaths (0 suicide deaths in youth taking antidepressants in the years 1995 to 1999) or attempts (Hazard ratio 1.59, 95 percent CL 0.89, 2.82), after controlling for a number of potential confounders. In fact, Valuk and colleagues found that youth who used antidepressants for 6 months or more were at reduced risk of suicide (HR 0.34, 95 percent CL 0.21, 0.55). The case-control study, however, did find an association between antidepressant use and suicide deaths (OR 15.62, 95 percent CI 1.65, ∞) and suicide attempts (OR 1.52, 95 percent CI 1.12, 2.07).^114^ Olfson and colleagues linked 263 individuals attempting suicide and eight suicide death cases with comparable controls in separate analyses, matching on multiple demographic, severity, and utilization factors. Results for suicide deaths should be interpreted cautiously, however, given the small number of cases.

Antidepressant use increased the risk of conversion from a unipolar depressive disorder to a bipolar disorder in a large good-quality cohort study of individuals aged 5 to 29 years.^115^ The conversion rate in patients using antidepressants was 7.7 percent per year, compared with 2.5 percent per year in those who did not use antidepressants. Further, there appeared to be a treatment-by-age interaction, where the difference in conversion rates between antidepressant users and nonusers was even larger in younger children—the rate ratio between users and nonusers was 2.9 in 5- to 14-year-olds (95 percent CI 2.8, 3.1) compared with 1.4 in 15-to 29-year-olds (95 percent CI 1.3, 1.5).

### Study details

We systematically searched for data describing the risk of serious adverse events including death, psychiatric hospitalization, suicidal ideation, suicidal attempts, discontinuation of medication due to serious adverse events, and triggering symptoms of mania. We considered evidence from RCTs, meta-analyses of RCTs, and large observational studies with appropriate control groups. During the past few years, numerous systematic evidence reviews and regulatory agency reports have synthesized available data from RCTs to estimate whether excess risk of suicide-related events occurs among depressed children or adolescents treated with SSRIs or atypical antidepressants.^65,^ ^66,^ ^90^–^92,^ ^110,^ ^111,^ ^116^–^124^ These reviews were each limited to the quality and quantity of data that were available at the time these analyses were conducted. For this report, we included the most recently published reviews that used suicide-related outcome data that were blindly classified by suicidology experts at Columbia University (requested by the FDA Division of Neuropharmacological Drug Products).^92,^ ^110,^ ^111^ Only one of these reports incorporated a recently published trial of escitalopram.^92^ The body of available RCTs is the same as those that are described for KQ 4. In addition to providing results from published reviews, we present the pooled results of suicide-related events for the nine RCTs that met all inclusion and exclusion criteria.

Hammad et al., 2006: ^110^ This good-quality report describes the meta-analyses conducted by the FDA, Division of Neuropharmacological Products to assess the risk of suicidality for pediatric patients treated with antidepressants. Data were included from 23 placebo-controlled trials of antidepressants (SSRIs and atypical antidepressants) in pediatric patients conducted by nine drug development programs and one placebo-controlled, multicenter trial funded by the NIMH (the TADS trial), including data from a total of 4,582 patients. The review focused on suicide-related events (SREs), including suicidal ideation and suicidal behaviors. The FDA requested the nine drug manufacturers of antidepressants to have blinded personnel electronically search their trial databases for text strings (e.g., suic-, overdos, self harm, attempt). Drug manufacturers provided narrative summaries for each SRE and also for any adverse events during trials that were identified as serious, accidental injuries, or accidental overdoses. Regulatory agencies define “serious adverse event” during pharmaceutical trials as any event that results in death, a life-threatening adverse drug experience, inpatient hospitalization, or prolongation of an existing hospitalization.

The FDA arranged for a group of 10 independent pediatric suicidology experts at Columbia University to blindly classify these potential SRE narratives. The experts categorized each event into one of five possible categories: suicide attempt, preparatory actions toward imminent suicidal behavior, suicidal ideation, self-injury with intent unknown, and injury events with not enough information to determine whether they represented self-injury or other injury. The first three categories most clearly represented suicidality and were the primary outcome of interest. The latter two categories were less certain and were included as a secondary outcome of “possible suicidal behavior or ideation”. The exposure window for eligible SREs was: adverse events that occurred during the double-blind acute treatment period or within 1 day of the end of this period. For patients who left the study early, only events that occurred before discontinuation or on the day after the last dose of the assigned treatment were included. Events that occurred before randomization or after the double-blind period were excluded to avoid confounding from a wide array of possible subsequent treatment scenarios. The most serious event was selected for patients who had more than one eligible event. The researchers pooled the results from all available data to generate overall estimates of the drug effects. They calculated Mantel-Haenszel RR and RD using a fixed-effects approach. They also calculated results using a random-effects model as a sensitivity analysis. In addition, the FDA scientists had access to all individual-level data describing multiple demographic, trial-related, disease-related, drug-related, and psychiatric history-related data. They were able to conduct stratified analyses to evaluate for potential effect modification and confounding variables.

In total, the experts identified 109 SREs, and an additional 11 events were recorded in TADS (n = 89 for primary outcome, n = 120 for secondary outcome). No suicide deaths occurred in any trial. The incidence of the primary outcome varied from 0 to 8 percent across the 24 individual antidepressant trials. Relative risk estimates varied even within the same drug and same indication (e.g., MDD, OCD). Overall, the RR of suicidality was 1.95 (95 percent CI 1.28, 2.98) across all trials. Separate analyses for suicidal ideation (RR 1.74, 95 percent CI 1.06, 2.86) were similar to those for suicidal behavior (RR 1.90, 95 percent CI 1.00, 3.63). The only individual trial to show a statistically significant increase in risk of suicidality in the drug-treated group was TADS (RR 4.62, 95 percent CI 1.02, 20.92), although the RR was ≥2 in seven other trials. The authors examined trial designs and inclusion and exclusion criteria to explain heterogeneity within trials, but found no consistent explanations for heterogeneity.

The pooled RR of SRE are presented in the first column of Table 9. Among the MDD trials (in bold-faced type), the pooled RR of SRE for all SSRIs combined was 1.66 (95 percent CI 1.02, 2.68). The RR estimates of SRE for individual types of SSRIs in the MDD trials were not statistically significant. The only individual drug type that had a statistically significant RR of SRE, either within MDD trials or for any indication, was a non-SSRI, extended-release venlafaxine (not shown in the table), for which the RR among the MDD trials was 8.84 (95 percent CI 1.12, 69.51). Results of sensitivity analyses did not yield substantial differences in RR estimates. Across all trials for all indications, the results for the overall RR estimate using a random-effects model (RR 1.75, 95 percent CI 1.11, 2.76) was slightly lower than when using the fixed-effects approach (RR 1.95, 95 percent CI 1.28, 2.98). Findings for the secondary outcome (including less certain suicidal events) (RR 2.19, 95 percent CI 1.50, 3.19) were also similar to the results for the primary outcome. The absolute risk difference for the primary outcome across all 24 trials was 0.01 (95 percent CI 0.01, 0.02). The absolute risk difference for the secondary outcome was 0.02 (95 percent CI 0.01, 0.03).

Table 9 Summary of suicide-related adverse events among children and adolescents treated with antidepressants (KQ 5)

Drug/Indication | RR (95% CI) | RD (95% CI) | RR (95% CI) | RD (95% CI)
Drug/Indication | Outcome
Suicide-related events^a^ | Suicide-related events^b^ | Serious adverse events^c^ | Suicide-related events^d^
Citalopram or Escitalopram/MDD | 1.37 (0.53 to 3.50) | -0% (-3% to 2%) | 1.21 (0.62 to 2.36) | -1% (-3% to 1%)
Fluvoxamine/MDD | No MDD trials | No MDD trials | No MDD trials | No MDD trials
Paroxetine/MDD | 2.15 (0.71 to 6.52) | 2% (-1% to 4%) | 2.70 (1.28 to 5.71) | 2% (-1% to 4%)
Fluoxetine/MDD | 1.53 (0.74 to 3.16) | 2% (-3% to 6%) | 1.40 (0.75 to 2.68) | 3 (-2% to 7%)
Sertraline/MDD | 2.16 (0.48 to 9.62) | 2% (-1% to 4%) | 3.31 (1.25 to 8.79) | 2% (-1% to 4%)
Focus of this report: All SSRIs/MDD | 1.66 (1.02 – 2.68) | NR | NR | 1% (0% to 2%)
All antidepressants/MDD | NR | 1% (-0.1% to 2%) NNH = 112 | 2.00 (1.43 to 2.79)
All newer antidepressants/any indication | 1.95 (1.28 to 2.98)^e^ | 0.7% (0.1% to 1.3%) NNH = 143
Source | Hammad, 2006^110^ | Bridge, 2007^92^ | Wallace, 2006^66^ | Primary analyses conducted for this report
Methods | Fixed-effects model meta-analyses | Random-effects model meta-analyses | Fixed-effects model meta-analyses | Random-effects model meta-analyses
All antidepressants N MDD N SSRI for MDD N | 4,582 NR NR | 5,310 3,430 NR | N/A 2,145 N/A | N/A N/A 2,013
Comments | Missing one escitalopram trial^84^ | | Missing one escitalopram trial^84^ | Restricted to fair- or good-quality RCTs

MDD = Major depressive disorder, SSRI = selective serotonin reuptake inhibitor, RR = risk ratio, RD = risk difference, OR = odds ratio

a Assessed by independent blinded suicidology experts at Columbia University

b Assessed by independent blinded suicidology experts at Columbia University for trials included in Hammad et al. 2006 and using similar methodology for trials not included in that report

c Serious adverse events include death, life-threatening symptoms including suicide attempts, hospitalization, significant disability or incapacity including mania, or events which jeopardize the patient and require medical intervention including study discontinuation. These were assessed from individual trial data.

d Using trial-level outcomes published in Bridge et al., 2007

e Excludes data from four trials in which no SRE occurred in either treatment or placebo control group

Bridge et al., 2007: ^92^ As described for key question 4, this good-quality systematic evidence review included meta-analyses of efficacy and suicide-related events for all pediatric antidepressant trials for all indications, with results stratified by indication (MDD trials separate from other indications). SRE were obtained from Hammad and colleagues for all trials included in the FDA analyses of SRE. For newer trials, Bridge and colleagues used the same type of methodology (blinded expert review of case narratives) and outcome classification to determine SRE. Bridge and colleagues reported risk differences and used random-effects models. Pooled results are reported in Table 9, based on 5,310 patients who were in RCTs of any antidepressant for any indication and the subset of 3,430 patients who were treated for MDD. The authors did not report results for SSRIs separately from other newer atypical antidepressants. The RD for all antidepressants for MDD was one percent (95 percent CI -0.1, 2; NNH = 112). They also report results by antidepressant type. The RDs for individual types of antidepressants (e.g., fluoxetine) ranged from zero to two percent and were not statistically significant for any single type of antidepressant. Patient- and trial-level characteristics were examined and none were related to suicide-related events.

Data were also reported separately for children and adolescents. Data for suicide attempts or preparatory acts were reported separately from suicidal ideation. When considering all SRE among children, the risk difference was one percent (95 percent CI -1, 3). Among adolescents, the risk difference was one percent (95 percent CI -0, 2). Within each subgroup of age and outcome type, rates of suicide-related events ranged from one to two percent among antidepressant-treated patients and from zero to one percent among placebo-treated patients. When SRE were separated into suicide attempts/preparatory acts and suicidal ideation, risk differences ranged from zero to one percent for children or adolescents separately and combined, and were not statistically significant within any subgroup.

Wallace et al., 2006: ^66^ This fair-quality meta-analysis assessed the efficacy and safety of SSRIs for pediatric MDD. Although this meta-analysis had several limitations, it assessed a broad range of adverse effects, beyond just suicide-related events, and thus was included in this review. The authors used a comprehensive search method through April 2005, but data from the escitalopram trial was not yet available. They assessed quality criteria and only included trials that met their quality criteria. Their sources of information for outcomes, however, were published results or, for unpublished trials, the Committee on Safety of Medicine website (UK regulatory agency subcommittee). Therefore, they did not use suicide-related outcomes based on the blinded Columbia review. Also, they did not have access to full published reports of trials, therefore their ability to conduct comprehensive quality rating may have been limited. The SAE outcomes they included were death; life-threatening symptoms including suicide attempts, hospitalization, significant disability or incapacity including mania; or events which jeopardize the patient and require medical intervention including study discontinuation. The authors used fixed-effects models for conducting meta-analyses. They lumped results from trials of newer atypical antidepressants with SSRIs. They included seven published RCTs and four unpublished RCTs. Their results are presented in Table 9. They report 108 SAEs among 1,129 SSRI- or atypical antidepressant-treated patients (9.6 percent) and 48 SAEs among 1,016 placebo-treated patients (4.7 percent). The relative risk was 1.97 (95 percent CI 1.42, 2.75), indicating that overall, patients treated with antidepressants had approximately twice the risk of having any type of serious adverse event. While results varied within drug types, results were not statistically significant for fluoxetine (RR 1.40, 95 percent CI 0.75, 2.68) or citalopram/escitalopram (RR 1.21 95 percent CI 0.62, 2.36). In contrast, RR were approximately three-fold higher and statistically significant among paroxetine- (RR 2.70, 95 percent CI 1.28, 5.71) or sertraline-treated (RR 3.31, 95 percent CI 1.25, 8.79) patients.

### Our own pooled SRE results

For our own analyses, we used the trial-level SRE data reported in the Bridge SER, which were either the outcomes used by the FDA or outcomes ascertained using equivalent methodology. We did not have access to these original patient-level results, therefore we could not verify the accuracy of the trial-level results reported in Bridge. We calculated the RD across all SSRIs and within SSRI subtypes, pooling among the nine trials that met our inclusion criteria (n = 2,013; Table 9). We found that the RD was one percent (95 percent CI 0, 2) (Figure 3). Among individual drugs, risk differences ranged from negative one to three percent, and none were statistically significant. For fluoxetine, the RD was three percent (95 percent CI -2, 7). As a sensitivity analysis, we recalculated the risk difference among all nine RCTs using a fixed-effects model, and results were similar (RD 1 percent, 95 percent CI 0, 3).

Figure 3. Suicidal ideation or behavior risk in children or adolescents treated with SSRIs for MDD

Nillson and colleagues report on longer-term outcomes of one of the fluoxetine trials,^88^ including data on adverse events for the entire 19-week study period.^125^ After the 9-week acute treatment phase, participants were followed for an additional 10 weeks. Participants continued to take either fluoxetine or placebo medication during this 10-week period as originally assigned. Participants in the fluoxetine group not showing a response to treatment were further randomized either to receive a change in dose or to remain at the same dose for the continuation phase. During the entire 19-week acute and continuation treatment, 11 participants in each group discontinued their medications due to adverse events (10.0 percent of fluoxetine group and 10.1 percent of the placebo group), and four participants in each group reported a suicide-related or self-harm event (3.7 percent of the fluoxetine group and 3.8 percent of the placebo group).

### Harms: SSRI + psychotherapy treatment

The TADS trial was the only trial that reported adverse effects of combined SSRI and psychotherapy treatment.^78,^ ^126^ In this study, several protocols were established across sites for assessing adverse events. An adverse event had to cause clinically significant interference with functioning, require medical attention, or be associated with impaired functioning and cause the patient to require a concomitant medication. Harm-related adverse events were those involving harm to the self, including non-suicidal events such as cutting oneself for relief of dysphoria. It also included worsening suicidal ideation without self-harm, suicide attempt of any lethality, or harm to others. Suicide-related adverse events required the patient to exhibit worsening suicidal ideation, make a suicide attempt, or both. Harmful behaviors without suicidal ideation or intent, such as cutting, are not included as suicide-related adverse events.

Although high-risk suicidality was an exclusion criteria for the TADS trial, 27 percent of patients had at least minimal suicidal ideation based on a suicide question on the CDRS-R, and two percent had severe suicidal ideation (across all four groups). When comparing the results for the suicidality outcomes, the suicide-related adverse event rate among the CBT + fluoxetine group was 6/107 (5.61 percent) compared with 4/112 (3.57 percent) in the placebo control group. The odds ratio was 1.60 (95 percent CI 0.44, 5.85), indicating that the rates were not statistically different from each other. Results of harm-related adverse events were slightly higher 9/107 (8.4 percent) for the fluoxetine + CBT group, but the odds ratio, comparing the risk with placebo control patients, was similar in magnitude and also not statistically significant. One patient in the CBT + fluoxetine group developed hypomania, while two patients in the placebo control group developed either hypomania or mania.

Emslie et al. (2006) have separately reported additional safety results from the TADS trial, restricting analyses to observed cases only and to patients who were still in their assigned treatment arm at the time of observation (i.e., did not receive any out-of-protocol treatments.^126^ Seventy-eight to 86 percent of patients remained in their treatment arms at 12 weeks and these rates were not significantly different between groups. They present results of suicide-related events measured by 1) self-report of suicidal ideation on the Suicidal Ideation Questionnaire for grades 7 to 9 (SIQ-Jr), 2) clinician-rated suicidal behavior on CDRS-R, and 3) Columbia Classification System. Mean SIQ-Jr score was higher at baseline in the combined treatment group (although not statistically significant). Although the mean SIQ-Jr scores were not statistically different between groups, the overall improvement in suicidal ideation was greater for the combined treatment group compared to the placebo group (p = 0.02). Both self- and clinician-rated measures were also analyzed for worsening and emergence of suicidality. Results varied depending on which measure and criteria were used, but differences were not statistically significant. Results of suicide-related events using the Columbia Classification system yielded higher rates of suicide-related events among the combination therapy group than the placebo group (4.7 percent vs. 2.7 percent) but no statistically significant difference.

Kaizar et al., 2006: ^111^ Using Bayesian meta-analytic approaches, Kaizar and colleagues re-analyzed the data from the FDA meta-analysis that led to the black box warning on antidepressant use for children. This series of meta-analyses examined variations in risk associated with drug formulation, drug class, study length, and indications for use. The authors also conducted a series of sensitivity analyses. In children and adolescents with MDD, use of any antidepressant was associated with a doubling of risk for suicidal behavior or ideation. Some, but not all, analyses suggested that risk was limited to use of any SSRI (as compared with atypical antidepressants such as bupropion). A commentary on this analysis notes that limited power complicates firm conclusions on lack of an effect on suicidality for non-SSRI antidepressants or for other psychiatric diagnoses,^127^ which supports the FDA's conservative interpretation of general caution in the use of antidepressants in children and adolescents.

### Observational studies

#### Suicide deaths and attempts

Valuck et al., 2006: ^112^ This good-quality, propensity-adjusted retrospective cohort study used data from a proprietary database of paid claims from 74 managed care plans in the US (covering the years 1997 to March, 2003) to examine whether antidepressant use increased the likelihood of a suicide attempt. They identified all members aged 12 to 18 years who received a diagnosis of MDD, an antidepressant dispensing, or both. The authors limited the sample to youth beginning new episodes of depression by eliminating those with claims indicative of depression or psychotherapy in the 12 months prior to the index claim. Suicide attempts were identified based on ICD-9 and ICD-10 codes, though suicide deaths, if any, were not reported. Antidepressant use was measured by dispensing claims and were categorized by type of antidepressant (TCA, SSRI (+ venlafaxine), other, multiple, or none), and measures of duration and compliance were calculated from the dispensing dates and days-supply dispensed. Their analyses included 24,119 youth and had an average of 1.36 years of followup data from the index claim, with a range of 6 months to 6 years with 3 months of followup.

Valuck and colleagues used a two-step approach to data analysis. First, they conducted a propensity analysis to address the fact that patients were not randomly assigned to the medication usage conditions. This is important because depression severity increases the likelihood of a suicide attempt and may also increase the likelihood that a youth would be given antidepressant medication, thus making it difficult to determine whether an increased rate of suicide attempts in antidepressant users would be due to the effects of the medication or due to the fact that they are more severely depressed than those who do not use medications. The propensity score quantifies the probability of receiving each type of treatment, given the following covariates: region, provider specialty, year of MDD diagnosis, age at time of first MDD diagnosis, gender, Medicaid status, number of chronic illnesses, presence of terminal diagnosis, presence of substance abuse diagnosis, presence of schizophrenia diagnosis, presence of other mental health diagnosis, and a log transform of the previous year's healthcare expenditures. Next, the propensity scores were used as continuous adjustment variables in a Cox proportional hazards model to model time until suicide attempt.

While this study did not find an increase in the risk of suicide attempts among those taking antidepressants, one model was adjusted with propensity scores and the covariates used to create the propensity scores. The medication group showing the largest effect was SSRIs (including venlafaxine), but the effect was not statistically significant (Hazard ratio 1.59, 95 percent CL 0.89, 2.82, p = 0.116). Further, this study found that those who used antidepressants for 6 months or more had a reduced risk of a suicide attempt (HR 0.34, 95 percent CL 0.21, 0.55, p < 0.001).

Sondergard et al., 2006: ^113^ This large-scale, fair-quality retrospective cohort study identified all Danish children (aged 10 to 17 years) who had received antidepressants (covering 1995-1999) and all suicide deaths in children aged 10 to 17 during the years 1995-1999. Additionally, they identified a randomly-selected cohort of 50,000 youth who were 10 to 17 years old as of 1/1/1995, subsequently dropping youth who died or emigrated in the intervening years through 1999. It was not clear whether the study authors excluded youth who were exposed to antidepressants from this control cohort.

This study found 19 suicide deaths among the 51,731 youth followed (2,569 of whom had received antidepressants). None of the 19 youth who committed suicide were using antidepressants at the time of their death. Five of these 19 had received antidepressants at some point during the observation period. A multivariate model predicting suicide attempt from age at suicide (10 to 17 vs. 18 to 22), sex, history of antidepressant use, and history of psychiatric service use found that antidepressant use was not an independent predictor of suicide (Rate ratio 4.47, 95 percent CI 0.95, 20.96).

Olfson et al., 2006: ^114^ Olfson and colleagues conducted a good-quality matched case-control study of suicide attempts and suicide deaths using Medicaid utilization and administrative databases and the National Death Index database. They identified the sample of individuals aged 6 to 64 years with one or more inpatient stays for depression, excluding patients without pharmacy data or with comorbid diagnoses indicating that antidepressant medications might be inappropriate. From this sample, suicide attempt cases were identified as those with a suicide attempt preceded by psychiatric hospitalization based on claims data, and suicide death cases were those with a cause of death of suicide in a national death database. Cases were eliminated from the potential control pool and up to five controls were selected for each case by matching on: age (± 3 years); sex; race or ethnicity; state; date of hospital discharge (±30 days); presence of a claim for substance abuse; recent claim indicating a suicide attempt; and use of an antipsychotic, stimulant, anxiolytic, or mood-stabilizing medication during the 60 days preceding their event date. For suicide attempts they analyzed 263 cases and 1,241 controls. For suicide deaths, the authors analyzed 8 cases and 39 controls.

This study found that children and adolescents who attempted suicide were more likely to be treated with antidepressants than those who did not attempt suicide (45.6 percent of cases used antidepressants vs. 36.1 percent of controls, OR 1.52, 95 percent CI 1.12, 2.07). Looking at specific agents, those 6- to 18-year-olds taking sertraline, a tricyclic, or venlafaxine were more likely to have attempted suicide than those who did not take an antidepressant, but youth taking other agents did not have an increased likelihood of a suicide attempt. Similarly, there was an association between suicide deaths and treatment with an antidepressant medication (OR 15.62, 95 percent CI 1.65, ∞). Youth suicide cases were more likely than controls to be treated with an SSRI (37.5 percent of cases used an SSRI vs. 7.7 percent of controls, OR 11.26, 95 percent CI 0.97, ∞, p = 0.005).

#### Conversion to Bipolar

Martin et al., 2004: ^115^ This good-quality retrospective cohort analysis examined whether antidepressant use affected the rate at which people aged 5 to 29 years with depression or anxiety diagnoses developed a bipolar illness (termed “manic conversion”) and whether the relationship between antidepressant use and manic conversion differed for people of different ages. Martin and colleagues used the MarketScan Research Database, a publicly available fee-for-service claims database with medical and pharmacy information from more than 200 different insurance companies covering more than 7 million people. After selecting all 5- to 29-year-olds with depression or anxiety diagnoses and pharmacy data available, they calculated start and end dates for antidepressant use, date of manic conversion (if any), and four indices of severity: (1) whether the primary diagnosis was for severe depression, mild depression, or anxiety; (2) the number of different psychiatric diagnoses in the year; (3) the presence of an inpatient psychiatric hospital stay; and (4) the total number of psychotropic medication categories used.

The study authors described two types of manic conversion: (1) early-onset (median 28 days), characterized by anxiety and akathisia, usually dissipating upon drug discontinuation; and (2) later-onset (median 91 days), more closely resembling classic mania and not dissipating as readily after medication discontinuation. This study focused only on the later-onset type and eliminated cases in which manic conversion occurred in the first 2 months of observation.

In their sample of 87,920 patients, 4,786 patients (5.4 percent overall, 6.0 percent per person-year) converted from depression or anxiety to a bipolar illness. The conversion rate among antidepressant-treated patients was 7.7 percent per year, compared with 2.5 percent per year in untreated patients (rate ratio 3.1, 95 percent CI 3.0, 3.2). Further, the conversion ratio between antidepressant users and nonusers was higher in the 5- to 14-year-olds (rate ratio 2.9, 95 percent CI 2.8, 3.1) than the 15- to 29-year-olds (rate ratio 1.4, 95 percent CI 1.3, 1.5). Number Needed to Treat to Harm (NNH) analyses showed that for SSRIs, 43 15-to 29-year-old patients would need to be treated to see one case of manic conversion while only 12 5-to 9-year-olds, 11 10-to14-year-olds, and 20 15-to 19-year-olds would need to be treated for one manic conversion.

Table 10 presents a summary of evidence for each key question.

Table 10 Summary of evidence quality by key question

No. of studies | Design | Limitations | Consistency | Applicability | Overall Quality | Summary of Findings
KQ 1. Does screening for depression among children and adolescents in the primary care setting improve health outcomes?
No evidence
KQ1a. Does screening increase the proportion of patients identified with and/or treated for depression?
No evidence
KQ2. Are depression screening instruments for children and adolescents accurate in identifying depression in primary care or school-based clinics?
9 | Screening accuracy studies using a valid reference standard | Younger ages poorly represented, majority of studies in school settings, few instruments examined in more than one study | Fair | Fair. Two studies conducted in primary care settings, one in community setting, six in school settings. | Fair | Two instruments demonstrated good sensitivity and specificity in primary care settings in adolescents. Only one study (in a community setting) included children younger than ten years of age, and the majority included adolescents 12 years or older. The large number of instruments and heterogeneity in samples and settings makes generalization across studies difficult and may explain the wide range of performance characteristics reported (sensitivity ranged from 18 to 100 percent and specificity ranged from 38 to 97 percent).
KQ3. What are the harms of screening?
No evidence
KQ4. Does the treatment of depression (SSRIs and/or psychotherapy) among screen-detected children and adolescents identified in primary care or comparable populations improve health outcomes?
SSRIs
9 | RCTs | No long-term outcomes; trials excluded patients with many comorbid disorders | Fair | Fair. Primarily conducted in research or specialty settings. | Good. (3 fair, 6 good) | SSRI users had higher response rates than those taking placebo medication, with an absolute risk difference between treatment and control groups of 12 percent (95 % CI 7, 16). Fluoxetine and citalopram both yielded statistically significant higher response rates. Data from meta-analyses of efficacy among children and adolescents analyzed separately suggested that SSRIs were less effective among children.
Psychotherapy
10 | RCTs | No data ages 7–8; limited data ages 9–10; short-term outcomes only | Good | Fair; only 2 trials in community clinics | Fair (6 fair, 4 good) | Most of the psychotherapy trials found that treated patients had higher response rates, remission rates, or a greater reduction in depression symptoms after interventions compared to a variety of different types of control conditions.
SSRI and Psychotherapy Combined
1 | RCT | Single study | N/A | Good | Fair (1 good-quality RCT) | Combined fluoxetine and individual CBT group showed a response rate of 71% vs. 35% in those taking placebo and receiving weekly clinical monitoring.
KQ 5. What are the serious adverse effects of treatments?
SSRIs
17 | RCTs, meta-analyses, cohort studies, case-control study | Inadequate power to assess suicidality | Fair | Fair | Fair | Even the most conservative estimates indicate that the risk of suicidality may increase absolutely by 1 or 2 percent.
Psychotherapy
No evidence

RCT-randomized controlled trial; MDD-major depressive disorder; SSRI-selective serotonin reuptake inhibitor; CBT-cognitive-behavioral therapy