# Methods

Using the methods of the USPSTF (detailed in Appendix B),^64^ we developed an analytic framework (Figure 1) and five key questions (KQ) to guide our literature search. KQ1 assessed direct evidence that screening programs for depression among average-risk child and adolescent primary care patients reduce morbidity and/or mortality. KQ1a examined whether screening increases the proportion of patients identified with and/or treated for depression. KQ2 addressed the accuracy of depression screening instruments for children and adolescents in identifying depression in primary care or school-based clinics. KQ3 examined the harms of screening for depression in children and adolescents. KQ4 addressed the effectiveness of treating screen-detected children and adolescents with SSRIs and/or psychotherapy. KQ5 assessed serious adverse effects of SSRI and/or psychotherapy treatments for depression in children and adolescents. In conjunction with members of the USPSTF, we restricted the scope of this report to include only SSRIs. Fluoxetine is currently the only agent FDA-approved to treat pediatric depression. We broadened the scope to include all SSRIs because they act through a similar mechanism to fluoxetine and are most commonly prescribed.^46^ Tricyclic antidepressants were demonstrated to lack efficacy in previous evidence reviews and newer atypical antidepressants are not approved for treating depression among youth.

Figure 1. Analytic framework

For all key questions, we searched for systematic reviews, meta-analyses, and evidence-based guidelines on depression screening, treatment, or associated harms in children and adolescents in the Database of Abstracts of Reviews of Effects (DARE), the Cochrane Database of Systematic Reviews (CDSR), MEDLINE, and PsycINFO from 1998 through May 2006. We also conducted a series of searches for each key question and reviewed the search results for applicability to all key questions. For KQs 1–3, addressing screening outcomes, accuracy, and harms, we searched for depression screening in children and adolescents in primary care to cover the time period since the previous USPSTF review (1998 through May 2007) in MEDLINE, PsycINFO, and the Cochrane Collaboration Registry of Clinical Trials (CCRCT) without restrictions on study designs. For KQ4, we searched for RCTs/CCTs of psychotherapy and SSRI treatment in children and adolescents in MEDLINE, PsycINFO, and CCRCT in two separate searches covering 1998 through May 2007 for psychotherapy and 2004 through May 2007 for SSRIs. For KQ5, we searched for adverse effects of SSRIs and psychotherapeutic treatment, without restrictions on study designs, in two separate searches covering 1990 through May 2007 for psychotherapy and 2004 through May 2007 for SSRIs. The search period for SSRI treatment trials (safety and efficacy) began in 2004 because several previous systematic reviews provided good coverage through 2004.^65,^ ^66^ Our search period for adverse effects of psychotherapy began in 1990 because harms of treatment were not addressed in the previous USPSTF review. Articles were also obtained from outside experts and through reviewing bibliographies of other relevant articles and systematic reviews. In addition to these searches for published trials, we searched pharmaceutical company and federal agency trial registries for unpublished trials of SSRIs. All searches were limited to articles in English. Inclusion and exclusion criteria specific to each question are detailed in Appendix B.

Two investigators independently reviewed all abstracts for KQs 4 and 5. The initial search for KQs 1–3 produced a very high yield (3,418 abstracts). Therefore, we used a modified approach to reviewing these abstracts, detailed in Appendix B. Two investigators evaluated abstracts against a set of inclusion/exclusion criteria, including independent review using design-specific quality criteria based on the USPSTF methods, supplemented by NICE^67^ criteria for quality of systematic reviews (Appendix B, Table B3). Two investigators critically appraised all studies excluded for quality reasons. Data from included studies were abstracted into evidence tables by one investigator and checked by a second. We found no data for KQs 1, 1a, and 3. Data synthesis for KQ2, psychotherapy (KQ4 & 5), combined psychotherapy and SSRI interventions (KQ4 and 5), and observational data on harms of SSRIs (KQ5) were qualitative because heterogeneity in the interventions, samples, and settings did not allow for quantitative synthesis. For evidence on the efficacy and adverse effects of SSRIs, we calculated pooled absolute risk differences using random effects models and narratively describe data from other meta-analyses. Details of our quantitative synthesis approach and rationale are described in detail in Appendix B.