# Introduction

## Scope and Purpose

We conducted this systematic review to aid the United States Preventive Services Task Force (USPSTF) in updating its 2002 recommendation on screening for child and adolescent depression among average-risk, primary care populations. This report summarizes the evidence for the benefits and harms of screening, the accuracy of primary care feasible screening tests, and the benefits and risks of treating depression using psychotherapy and/or selective serotonin reuptake inhibitors (SSRIs) among patients aged 7 to 18 years. We focus on Major Depressive Disorder (MDD) and do not address screening or treatment for minor depression or dysthymia. This review summarizes the current state of the evidence relevant to primary care clinicians and identifies key gaps in this scientific literature.

## Condition Definition

Clinical depression is a condition characterized by persistent unhappiness or a loss of interest or pleasure in most activities. Among children and adolescents, irritability, rather than sadness, may be the predominant mood and can be accompanied by tantrums or verbal outbursts. Additional accompanying behavior patterns may include social isolation, deterioration in schoolwork, and expression of anger. Sleep and appetite disturbances can occur and may manifest as complaints of tiredness or nonspecific pain, such as stomach aches or headaches. When symptoms cluster together and persist for two weeks or more, major depressive disorder (MDD) may be present.

The American Psychiatric Association has established diagnostic criteria for depressive disorders among youth (Table 1).^1^ While dysthymic disorder (DD) is similar to MDD, it is generally longer lasting and less severe. A variety of terms are used for people with depressive symptoms whose depression does not meet criteria for MDD or DD, such as subthreshold depression, subsyndromal depression, and minor depression. Bipolar disorder, a mutually exclusive clinical entity from MDD, is characterized by episodes of abnormally elevated mood in addition to depression. Compared to younger pre-pubertal children, adolescents with MDD are more likely to experience an inability to gain pleasure from enjoyable experiences (that is, anhedonia), hopelessness, increased sleeping, weight change, use of alcohol or illicit drugs, and have more lethal suicide attempts. In contrast, children are more likely to experience somatic complaints, psychomotor agitation, separation anxiety, phobias, and hallucinations than adolescents.^2^

Table 1 Diagnostic criteria for primary DSM-IV depression disorders in children and adolescents^1^

A. Depressive Diagnoses | B. Symptoms
Major Depressive Episode:; - 5 or more depressive symptoms from column B for ≥ 2 weeks; - Must have either depressed mood or loss of interest or pleasure; - Symptoms must cause significant distress or impairment; - No manic or hypomanic behavior; Minor Depressive Episode:; - 2–4 depressive symptoms from column B for ≥ 2 weeks; - Must have either depressed mood or loss of interest or pleasure; - Symptoms must cause significant distress or impairment; - No manic or hypomanic behavior | 1 Depressed mood or irritability; 2 Markedly diminished interest or pleasure in most or all activities; 3 Significant weight loss (or poor appetite) or weight gain, or failure to gain appropriate weight; 4 Insomnia or hypersomnia; 5 Psychomotor retardation; 6 Fatigue or loss of energy; 7 Feelings of worthlessness or excessive or inappropriate guilt; 8 Diminished ability to think or concentrate, or indecisiveness; 9 Recurrent thoughts of death (not just fear of dying), or suicidal ideation, plan, or attempt
Dysthymic Disorder:; - Depressed mood or irritability for most of the time for at least one year; - Presence of 2 or more symptoms of dysthymia from column B; - Never without symptoms for 2 months or more over a one year period; - Symptoms must cause clinically significant distress or impairment; - No major depressive disorder in first year; no manic, hypomanic, or mixed episodes | 1 Significant weight loss (or poor appetite) or weight gain, or failure to gain appropriate weight; 2 Insomnia or hypersomnia; 3 Fatigue or loss of energy; 4 Low self-esteem; 5 Diminished ability to think or concentrate, or indecisiveness; 6 Feelings of hopelessness

## Prevalence and Burden of Disease/Illness

MDD has been increasingly recognized among youth and is surprisingly common, particularly among adolescents (Table 2). A recent meta-analysis estimated the prevalence of MDD among adolescents aged 13 to 18 years to be 5.6 percent. Prevalence estimates were based on psychiatric interviews for nearly 60,000 youth from varying time frames (1, 3, 6, and 12 months).^3^ Gender differences in prevalence are present among adolescents, with higher prevalence among girls than boys (5.9 vs. 4.6 percent).^3^ Lifetime prevalence among adolescents may be as high as 20 percent.^4^–^6^ Depression is less common among children younger than 13 years, among whom prevalence of MDD is estimated to be 2.8 percent.^3^ Point prevalence of MDD among adolescents in primary care settings has ranged from 9 to 21 percent.^7^–^9^

Table 2 Reported prevalence of Major Depressive Disorder (MDD) and Dysthymia in community and primary care samples

Sample (ages if provided) | Prevalence Estimate
Current* MDD, community samples^3^
Younger children (under age 13) | 2.8%
Adolescents (13–18) | 5.6%
Adolescent girls (13–18) | 5.9%
Adolescent boys (13–18) | 4.6%
Lifetime MDD, community samples^4^–^6^
Adolescents (13–18) | 4.0% – 24.0%
Adolescent girls (13–18) | 4.5% – 31.6%
Adolescent boys (13–18) | 2.9% – 15.2%
Current MDD, primary care samples
Younger children (4–9)^157^ | 0.7%
Children and adolescents (6–18)^158^ | 11.0%
Current Dysthymia, community sample^159^
Adolescents | 3.1%
Lifetime Dysthymia, community sample^6^
Adolescents | 4.9%
Adolescent girls | 5.3%
Adolescent boys | 2.3%

* Data from a meta-analysis combining 1 to 12 month prevalence estimates

As many as 8 percent of youth with adolescent-onset depression are estimated to have completed suicide by young adulthood.^10^ Such youth may also have a five-fold increase in risk of attempting suicide compared to non-depressed adolescents.^10^ Suicide is the third leading cause of death among those aged 15 to 24 years and the sixth leading cause among those aged 5 to 14 years.^11^ The majority of adolescents who have completed suicide had longer-term MDD.^12^

MDD is also associated with substantial long-term morbidity, including decreased school performance, poor social functioning, early pregnancy, increased physical illness, and increased risk of substance abuse.^10,^ ^13,^ ^14^ Depressed adolescents have more psychiatric and medical hospitalizations than adolescents who are not depressed.^10^ Additionally, the cost of medical care (general medical combined with mental health care) is higher for children with depressive disorders than children without mental health diagnoses and children with other mental health diagnoses (other than conduct disorder).^15^ Young adults who have adolescent-onset MDD are at increased risk of impairment in work, social interactions, and family functioning.^10,^ ^16^

## Natural History

While depression can begin at any age, a substantial proportion of patients have their first episode of MDD during childhood or adolescence. Cumulative Kaplan-Meier curves for age-at-onset show that risk is fairly low until the early teens, at which time it rises in a roughly linear fashion.^17^ One study of adult primary care patients (40.5 years of age, on average) found that 38 percent of depressed patients' initial onset of MDD was before age 18.^18^ The average length of a major depressive episode in children and adolescents is approximately 7 to 9 months.^19^ Factors associated with longer time to recovery in children and adolescents include earlier age of onset, greater severity of illness, suicidality, presence of comorbid dysthymia, anxiety, disruptive disorders, maladaptive cognitive patterns, and adverse family environment.^20^ Like adult depression, depression in children and adolescents is often recurrent, with estimates of recurrence ranging from 40 to 70 percent.^19^ These rates may overestimate the general risk, however, as they are based on small, non-community-based samples.

Adolescent MDD is particularly associated with increased risk of MDD occurrence in early adulthood in both clinical and community samples.^10,^ ^14,^ ^21^ Among a school-based sample of adolescents with MDD, 46 percent experienced a major depressive episode between the ages of 19 and 23 years, and an additional 22 percent had a non-mood-related psychiatric disorder between the ages of 19 and 23 years.^21^ Among adolescents with an MDD diagnosis, risk factors for MDD in young adulthood include high levels of emotional reliance, multiple major depressive episodes in adolescence, higher proportion of family members with recurrent MDD, high levels of antisocial or borderline personality disorder symptoms, negative attributional style (males only),^14^ and low SES.^22^ The relationship between onset of MDD prior to adolescence and MDD in adulthood, however, is not clear.^23^

An additional outcome of concern is that MDD may convert to a bipolar disorder, which involves episodes of mania or hypomania and often also includes psychosis. The rate of conversion to a bipolar illness is higher in adolescents than in adults. Twenty to thirty percent of clinically referred youth with a diagnosis of MDD will develop a bipolar illness during the subsequent 5 to 10 years.^19^ This is a considerably higher rate than that of adults, which is estimated at less than 10 percent.^19^ Another complicating factor of MDD is that it frequently co-occurs with other mental health disorders. One study of adolescents with MDD from mental health clinic and school populations found that 76 to 78 percent had an additional mental health disorder, most commonly anxiety disorders.^24^

## Etiology

A variety of factors contribute to the development of depression, with most people who develop MDD having multiple risk factors.^25^ Researchers have identified several familial and personal factors that appear to increase the risk of depression, such as parental depression, sub-syndromal depression, anxiety, neurobiology, temperament/personality, negative cognitions, stress, and interpersonal conflict.^26^ In addition, negative life events^27^ and health issues, such as chronic pain,^28^ may increase the likelihood of depression. The role of genetics in the development of depression is unclear. Twin studies support the heritability of depressive symptomatology,^29^ and one twin study of adolescent girls reported moderate heritability (41 percent) of a depressive disorder meeting DSM-IV criteria.^30^ In contrast, two adoption studies do not support a genetic component of depression.^31,^ ^32^

These risk factors may contribute directly to the development of depression or may increase the likelihood that a young person who is faced with negative life events or chronic stressors will become depressed. Several of these factors have multiple presumptive pathways for increasing the risk of depression. Having a depressed parent, for example, may increase risk due to both genetic predisposition to depression inherited from the parent and the effects of the depressed parent's behavior, who are more likely to be irritable and inconsistent and less warm and interactive than parents who are not depressed.^33^ Similarly, many of these factors are likely to interact with each other to increase depression risk. Genes may contribute to a child's neurochemistry, personality, and ability to self-regulate, which may cause others to react more negatively to them, thus creating a more depressogenic environment.

## Prevalence in Subgroups with Risk Factors

As risk factors for depression are difficult to assess, researchers have focused on identifying subgroups of youth who have an increased risk of developing depression. Some examples of factors that can be assessed relatively accurately and reliably include being an offspring of depressed parents, having comorbid mental health or chronic medical conditions, and having suffered a major negative life event. Prevalence of depression is considerably higher among some of these subgroups than in the general population (Table 3). For example, a study identified 20 to 33 percent of obese youth as having depression.^34^ Among youth with psychiatric comorbidities, the majority of studies from several reviews found that 10 to 30 percent of youth with an anxiety disorder also had a depressive disorder,^35^–^37^ with individual studies reporting prevalence as high as 69.2 percent.^36^ Offspring of depressed parents also have a high prevalence of depression. By the age of 18 years, 40 to 67 percent of these youth are estimated to have met criteria for depression at some point during their lives.^38^

Table 3 Prevalence of depressive disorders in subgroups at risk for depression (chronic medical or mental health conditions)

| Depressive Disorder* | Prevalence | Ages (if provided)
Chronic Medical Conditions
Asthma^160.^ ^161^ | MDD | 2.7% | 5 to 11
| Dysthymia | 4.9% | 8 to 15
Epilepsy^162^ | Mood** | 24.6% | 5 to 16
Celiac Disease^163^ | MDD | 7.0%
| Dysthymia | 7.0%
| Mood** | 17.0%
Recurrent Abdominal Pain^164^ | MDD | 31.0%
| Dysthymia | 9.5%
| Mood** | 42.9%
Obesity (community setting)^34^ | Mood** | 20.0% | 13 to 21
Obesity (clinical setting)^34^ | Mood** | 33.3% | 13 to 21
Mental Health Conditions
Anxiety^35^–^37^ | Mood** | 10 – 30%
Generalized Social Anxiety Disorder^165^ | MDD | 6.0% | 8 to 17
CD/ODD^36^ | Mood** | 10.9 – 20.4%
ADHD (general population)^36^ | Mood** | 7.2 – 13.2%
ADHD (psychiatric setting)^158^ | MDD | 50% | 6 to 18
ADHD (pediatric setting)^158^ | MDD | 42% | 6 to 18
PTSD^166^ | Lifetime MDD | 41.7% | at 18
Negative Life Events
NYC post-9/11: Severe exposure^167^ | MDD | 11.0% | 9 to 21
NYC post-9/11: Moderate exposure^167^ | MDD | 8.0% | 9 to 21
Other
Parental Depression^38^ | Lifetime MDD | 40.0% – 67.0% | at 15 to 20

* Meeting diagnostic criteria based on diagnostic interviews

** Mood=Any mood disorder

MDD=Major Depressive Disorder; CD/ODD=Conduct Disorder/Oppositional Defiant Disorder; ADHD=Attention Deficit/Hyperactivity Disorder; PTSD=Post-traumatic Stress Disorder; NYC post 9/11=New York City residents after terrorist attack on 9/11/2001

## Rationale for Screening/Screening Strategies

Mass screening in primary care could help clinicians identify missed depression cases and initiate appropriate treatment. Screening could also help clinicians identify patients earlier in their course of depression. In both cases, it would be necessary to deliver effective treatment that would improve patients' depression and more quickly alleviate suffering.

Current tools for assessing children and adolescents for depression include diagnostic interviews and symptom rating scales.^39^ Several of these tools are long and complex and have primarily been evaluated in non-primary care settings. Diagnostic screening tools, however, have been developed which are feasible for use in primary care (Table 4). In some cases, tools designed for adults have been used directly with, or adapted for, adolescents. Some tools have been developed specifically for younger children and consider developmental differences. Relatively few available tools have been designed for use with children or adolescents specifically in the primary care setting.

Table 4 Screening instrument descriptions and diagnostic tools

Instrument | Abbreviation | Age (years) | Number of Items | Score Range | Typical Cutoff | Time to Complete (minutes)
Screening Instruments
Beck Depression Inventory^168^ (self-report) | BDI | ≥14 | 21 | 0–63 | 11 (female adolescents) 15 (male adolescents) | 5–10
Center for Epidemiological Studies-Depression Scale^169^ (self-report) | CES-D | ≥14 | 20 | 0–60 | 24 (female adolescents) 22 (male adolescents) | 10
Center for Epidemiological Studies-Depression Scale for Children^170^ (self-report) | CES-DC | 12–18 | 20 | 0–60 | None identified | 5–10
Children's Depression Inventory^171^ (self-report and/or parent/ other care-giver report) | CDI | 7–17 | 27 | 0–54 | 19 | 10–15
Mood and Feelings Questionnaire^172^ (self-report and parent-report) | MFQ | 8–18 | 33 (child) | 0–66 | 29 | 5–10
| | | 34 (parent) | 0–68 | None identified
Short Mood and Feelings Questionnaire^128^ (self-report) | SMFQ | 6–17 | 13 | 0–26 | 8 (child) 12 (child + parent) | 5–7
Patient Health Questionnaire for Adolescent^7^ (self-report) | PHQ-A | 13–18 | 67 | (n.a.) | Scoring algorithm | 5–10
Revised Clinical Interview Schedule (computer-based)^77^ (self-report) | CIS-R | unknown | varies | (n.a.) | Scoring algorithm | No data found
Reynolds Adolescent Depression Scale^173^ (self-report) | RADS | 13–18 | 30 | 30–120 | 77 | 5–15
| RADS-2 | 11–20 | 30 | 30–120 | 76
Reynolds Child Depression Scale^174^ (self-report) | RCDS | 8–12 | 30 | 30–121 | None identified | 10–15
Strengths and Difficulties Questionnaire^175^ (self, parent, and teacher report available) | SDQ | unknown | 25 | (n.a.) | Scoring algorithm (combines available reports) | 5–10

Instrument | Abbreviation
Structured Diagnostic Tools
Child Assessment Schedule^176^ | CAS
Composite International Diagnostic Interview ^177^ | CIDI
Development and Well-Being Assessment^178^ | DAWBA
Diagnostic Interview for Children and Adolescents^179^ | DICA
Revised Diagnostic Interview Schedule for Children^180^ | DISC-R
Schedule for Affective Disorders and Schizophrenia for School-Aged Children^181^* | K-SADS

* Semi-structured

Mass depression screening was feasible and acceptable from the provider's perspective in a recent pilot study.^40^ In this study, adolescents presenting to a pediatric primary care practice for health maintenance or urgent care visits were asked to complete a paper and pencil screening tool prior to their office visit. Front desk staff were involved in administering the tool and providers underwent special training in depression assessment. At the end of the study, providers reported that the burden of the program was low and that the patients were generally satisfied with the screening process. All 11 providers wanted to continue the screening program after the 6-month study period. The 13- to 17-year-old primary care patients in their study were able to complete a paper and pencil screening tool in less than 5 minutes. Few details were provided regarding the type of clinic or characteristics of the patients, therefore it is not clear how well the results would generalize to different types of clinical settings.

## Interventions/Treatment

Available modes of treatment for MDD in youth include pharmacotherapy (Table 5) and psychotherapy, delivered singly or in combination. Trials demonstrating the efficacy of drug treatments and time-limited psychotherapies among pediatric populations were first published during the 1990s.^2^ Presently, fluoxetine, an SSRI, is the only pharmacologic agent that the FDA has approved for the treatment of pediatric MDD. The term “psychotherapy” refers to a broad range of psychological interventions that may employ a variety of techniques, over different periods of time, and be based on different theoretical assumptions. Psychotherapeutic interventions may be very structured and manual-based or may be relatively unstructured. They may involve a variety of techniques, such as identifying and changing maladaptive behaviors or thought patterns, improving social or life skills, and empathetic listening and reflection on a patient's thoughts.

Table 5 Second-generation antidepressant drugs

Category | Drug Class | Generic Names
Second-generation | Selective Serotonin Re-uptake Inhibitors (SSRIs) | Fluoxetine*, Fluvoxamine, Paroxetine, Sertraline, Citalopram, Escitalopram
Second-generation | Selective Norepinephrine Re-uptake Inhibitors | Venlafaxine, Mirtazapine, Duloxetine
Second-generation | 5-HT2 Receptor Antagonists | Nefazodone
Second-generation | Dopamine Re-uptake Inhibitors | Bupropion

* Fluoxetine is the only antidepressant FDA-approved to treat pediatric depression

## Recent Controversies Regarding Treatment

In 2004, the FDA released a black box warning about suicidality and antidepressant use in pediatric patients. A blinded analysis of suicidality outcomes by suicidology researchers from Columbia University played an early role in the ultimate release of an FDA black box warning. There have subsequently been numerous publications discussing this issue, including the publications of the findings from the FDA meta-analyses evaluating risk of suicidality among pediatric patients treated with antidepressants. The FDA's analyses included a total of 4,582 patients from 24 trials. We describe their methodology and findings as part of our results.^21^

## Current Clinical Practice

### Identification of Depression

Current, reliable data describing pediatric depression screening practices among primary care providers are lacking. Available information from the past decade is based on clinician self-report. Providers in community health centers have reported screening 64 percent of their patients for depression, though they only documented their screening efforts in 3 percent of the patients.^41^ Providers in an HMO estimated screening an average of 46 percent of their patients for depression.^42^ Data based on direct observation or provider- and/or patient-report after specific clinical encounters would be more reliable. We are not aware of recent data describing the proportion of depressed children or adolescents who have been seen by a primary care provider but were not identified by the provider as depressed (i.e., missed cases). One older (1988) study found that pediatricians identified only 17 percent of children with behavioral or emotional problems.^43^

When asked to recall the identification methods used with their last depression patient, only one of 245 providers reported using a structured screening questionnaire.^44^ Providers in this same study reported that in 68 percent of their cases the presenting problem indicates that depression is a likely concern. This is concerning because depressed youth may not directly seek help with their depression from their provider. A recent Norwegian study found that youth with anxiety and depressive symptoms rarely sought treatment—only 34 percent of those in the 99^th^ percentile for symptom severity sought treatment—despite a health care system with free services that are relatively easy to access.^45^ Other commonly used clues for identifying depression in youth are the patient's appearance, reports or observations of family dynamics, and family members' concern for identifying a patient as possibly depressed.^44^

Once they identified depression as a likely problem, 50 percent of pediatricians based their diagnosis on their overall impression and inquiry about one to two symptoms. Only 17 percent used formal DSM-IV criteria for assigning a diagnosis. Once depression was diagnosed, 92 percent of pediatricians reported further assessment of specific symptoms and contributing factors.

This same study reporting on identification practices also queried providers regarding their beliefs about their role in identifying depression and their confidence in their ability to identify depression.^44^ They found that 90 percent of pediatricians believe that recognition of child and adolescent depression is their responsibility, but 46 percent lacked confidence that they could recognize depression.

### Treatment of Depression

Among youth identified in primary care as being depressed, the majority appear to receive treatment.^46^–^48^ During the year 1998, 69.7 percent of youth with visits in primary care for newly identified episodes of depression were either seen by a mental health specialist or received one or more dispensing of psychotropic medication in an HMO^46^ in the subsequent 30 to 90 days. Similarly, data from the National Ambulatory Medical Care Survey (NAMCS) and the outpatient component of the National Hospital Ambulatory Medical Care Survey (NHAMCS) showed that of adolescent primary care visits in which depression is reported, antidepressants were prescribed 52 percent of the time, and 68 percent of the visits included psychotherapy or counseling.^47^

Provider beliefs and perceptions. Despite these high rates of treatment reported in primary care visits where depression is noted, a survey of pediatricians found that only about a quarter of pediatricians believe that treating child and adolescent depression is their responsibility.^44^ Further, 86 percent of pediatricians were not confident that they could successfully treat child and adolescent depression with medication,^44^ and 90 percent of pediatricians were not confident that they could successfully treat child or adolescent depression with counseling.^44^ According to this survey, the main barriers to treating depression in youth for pediatricians are: inadequate time to provide counseling or education (endorsed as a barrier by 68 percent of surveyed pediatricians), inadequate time to collect an adequate history (56 percent), incomplete training to diagnose or counsel (56 percent), and incomplete knowledge of treatment for depression (44 percent).^44^

Modes of depression treatment. Psychotherapy is the most common mode of treating depressed youth. Of children treated for depression identified by a large community survey, 79 percent received psychotherapy.^48^ Although pediatric providers' use of counseling may be declining,^47^ they report using counseling in 68 percent of visits involving depression, and 35 percent of youth identified with a new episode of depression in primary care were seen by a mental health specialist within 90 days.^46^

Antidepressant use is also an important treatment modality for adolescents. In the US during 2002, 17/1000 (1.7 percent) of all children (0 to 18 years old) used antidepressants.^49^ Of children treated for depression identified by a large community survey, 57 percent received antidepressants.^48^ In primary care settings, over half of those treated for depression are prescribed antidepressants.^46,^ ^47^ The most commonly used medications are SSRIs: among all youth dispensed a psychotropic medication for a new episode of depression in an HMO in 1998, 78.8 percent received an SSRI, 3.6 percent received a TCA, 13.9 percent received another antidepressant (bupropion, nefazodone, trazodone, or venlafaxine), 2.3 percent received a mood stabilizer, and 1.3 percent received a benzodiazepine.^46^

Trends in the use of antidepressants. Several studies show that antidepressant use in youth increased steadily from the early- to mid-1990s until concerns about suicidality appeared in the early 2000s.^47,^ ^50^–^52^ From 1997 to 2002, antidepressant use went from 21/1000 (2.1 percent) to 39/1000 (3.9 percent) in those aged 13 to 18 years and stayed steady in younger children: 15/1000 to 14/1000 in those aged 6 to 12 years old and 1/1000–1/10,000 in those 0 to 5 years old according to a Medical Expenditure Panel Survey (MEPS) database.^52^ The use of SSRIs in particular have increased since the early- to mid-1990s.^47,^ ^52^ SSRI use was documented in 1.35 million outpatient child and adolescent visits in the 2001 to 2002 NHAMCS and NAMCS, which is a 2.6-fold increase from 1995 to 1996. Fluoxetine increased by 100 percent, sertraline by 62 percent, and paroxetine by 269 percent between 1995 to 1996 and 2001 to 2002. At the same time, TCA antidepressant use declined from 16 percent to 2 percent.^47^

The number of children and adolescents prescribed antidepressants in the US declined after the 2004 FDA public health advisory of black box warning.^53,^ ^54^ From April 2002 to February 2004, the number of prescriptions increased by a monthly average of 0.79 percent. From February 2004 (when there was an FDA hearing on SSRI safety that was widely covered by the media) through July 2004, there was a monthly decrease of an average of 4.23 percent.^53^ The same change in prescribing trends has been observed when including data through September 2005 and restricting to pediatric patients who have received a newly documented diagnosis of depression.^55^

In contrast to the increase in antidepressant use in adolescents from the early 1990s through early 2000s, suicide trends in adolescents and young adults steadily declined from 1994 through 2002.^56^ The downward trend, however, may be reversing: suicide rates in children and adolescents increased by 14 to 18 percent between 2003 and 2004 (when the black box warning appeared).^57,^ ^58^

## Recommendations of Other Groups

Routine screening for emotional and behavioral problems has been recommended by Medicaid's Early and Periodic Screening, Diagnostic and Treatment (EPSDT) program, the American Academy of Pediatrics, and the American Medical Association. The Canadian Task Force on Preventive Health Care concluded in 2004 that there was insufficient evidence to recommend for or against screening for depression among children or adolescents in primary care settings.^59^ The Society for Adolescent Medicine supports the initiation and continued use of antidepressant medications for adolescents when clinically warranted with close monitoring for emergent suicidality, hostility, agitation, mania, or unusual changes in behavior.^60^

## Previous USPSTF Recommendation

In 2002, the USPSTF concluded there was insufficient evidence to recommend for or against routine screening of children or adolescents for depression (I Recommendation).^61^ At the time of the 2002 review, no evidence was available describing the direct health outcomes among children or adolescents identified with MDD through primary care screening. While a small number of studies evaluated screening test performance in ambulatory, non-psychiatric pediatric populations, most of the data were from adolescent populations. Trials evaluating MDD treatment among children or adolescents indicated that tricyclic antidepressants were not effective and cognitive-behavioral therapy was efficacious among school populations. Only two controlled trials had been published describing the efficacy of SSRIs among youth, and these demonstrated mixed results.^62,^ ^63^ For both screening and treatment, it was unclear whether available results were generalizable to children or primary care settings. The previous report did not specifically search for literature on the harms of screening or the adverse effects of treatment.