# Discussion

The practice of prescribing aspirin to asymptomatic women for the prevention of myocardial infarctions has been called into question after the publication of a recent large study in women and a meta-analysis that reported no benefit. (4, 8) In the past, many organizations have recommended aspirin for the prevention of first myocardial infarctions in both men and women. These recommendations were based on studies primarily of men. The new evidence from the Women's Health Study and the meta-analysis with sex-specific calculations (4, 8) help clarify the differing benefits of aspirin for men and women. This evidence demonstrates that aspirin use reduces the number of CVD events in both men and women without known CVD. Men in these studies experienced fewer myocardial infarctions, and women experienced fewer ischemic strokes. Aspirin does not seem to affect CVD mortality or all-cause mortality in either men or women. Aspirin use for the primary prevention of CVD events likely provides more benefits than harms to men at increased risk for myocardial infarction and women at increased risk for ischemic stroke. The reason for the differences by sex is unknown. Several potential explanations have been posited (8), including differences in aspirin metabolism, differences in rates of myocardial infarctions and stroke, and higher likelihood of aspirin resistance in women.

The use of aspirin in primary prevention increases the risk for major bleeding events, primarily gastrointestinal bleeding events, in both men and women. Men have an increased risk for hemorrhagic strokes with aspirin use, whereas a new RCT and meta-analysis (4, 8) suggest that the risk for hemorrhagic strokes in women is not significantly increased. Some factors, such as whether the patient is receiving proton-pump inhibitors, may modify the risk for gastrointestinal bleeding. We did not specifically review this evidence. Future reviews should include a thorough review of the effect of proton-pump inhibitors and other factors on the incidence of gastrointestinal bleeding.

We found 1 study, a subgroup analysis of the previously published Primary Prevention Project study (15), that suggests that aspirin may have less benefit in diabetic patients than in nondiabetic patients. As a subgroup analysis, it has inherent limitations. Further research is needed to establish the benefit of aspirin use in diabetic patients for the primary prevention of CVD events. Another subgroup analysis, of the Hypertension Optimal Treatment study (14), reported that patients with higher baseline blood pressures had a greater than average benefit in the reduction of CV events without an increased risk for major bleeding events. These findings contrast with the findings of 2 other primary prevention trials, the Physicians Health Study and the Thrombosis Prevention Trial. (10, 11), which found less benefit for patients with higher systolic blood pressure. Further research is needed to clarify the benefit of aspirin in the prevention of CVD events in relation to blood pressure.

The dosages used in the primary prevention trials ranged from 75 mg/d to 500 mg/d. The Women's Health Study used 100 mg every other day. Some experts have suggested that the low dose used in the Women's Health Study may be a reason why no effect was seen in the reduction of the combined outcome of CVD events or in the reduction of heart attacks.

In summary, consistent evidence from randomized clinical trails indicates that aspirin use reduces the risk for CVD events in adults without a history of CVD. Men have a reduced risk for myocardial infarctions, and women have a reduced risk for ischemic strokes. Consistent evidence shows that aspirin use increases the risk for gastrointestinal bleeding events and limited evidence shows that aspirin use increases the risk for hemorrhagic strokes. The overall benefit in the reduction of CVD events with aspirin use is dependent on baseline CVD risk and risk for gastrointestinal bleeding.