# Results

The literature search initially identified 726 potentially relevant articles (Figure 2). We excluded most studies because either the sample population comprised only patients at very high risk for CVD or with a history of CVD or the study did not evaluate aspirin for the primary prevention of CVD. We also excluded studies that were duplicates or provided no new information, were not of appropriate study design, or did not report outcomes of interest. We ultimately included 4 studies, which we discuss. The 4 studies provided information on both benefits and harms.

Figure 2. Study flow diagram

## Key Question 1. Does aspirin use in men and women without known cardiovascular disease decrease coronary heart events, strokes, death from coronary heart events or strokes, or all-cause mortality?

New evidence from controlled trials is limited to one study in women, the Women's Health Study (4), that reported benefit in the reduction of ischemic strokes with aspirin use. The Women's Health Study was a good quality, double-blind RCT that evaluated the risks and benefits of aspirin in the primary prevention of cardiovascular disease. The investigators reported a benefit from aspirin use for the reduction of strokes (Relative Risk [RR], 0.83; [95% CI, 0.69 to 0.99]), specifically ischemic strokes (RR, 0.76 [CI 0.63 to 0.93]), and no statistically significant benefit in the reduction of combined cardiovascular events, myocardial infarctions, death from CVD, or all-cause mortality. We considered this study to be of good quality because a blinded end point committee of physicians reviewed medical records for all reported end points; analyses were completed using an intention-to-treat process, and the follow-up rate was high. The investigators did not report information on rates of compliance or crossovers.

A recent good quality meta-analysis (8) suggests differential benefits of aspirin by sex: men derive benefit in the reduction of myocardial infarctions and women derive benefit in the reduction of ischemic strokes. Although this meta-analysis includes studies that were published before our search dates, we include it here because it provides new estimates of sex-specific benefits and harms and is of appropriate quality that we thought it unnecessary to duplicate the updated calculations. (5) Berger and colleagues' search differed from ours in that we searched for recent studies published since 2001 and we used the broader term cardiovascular disease, whereas Berger used the specific terms myocardial infarction and stroke. We also used additional terms to search for studies on the harms of aspirin and accepted study types other than RCTs. Berger and colleagues' meta-analysis (8) reported on the sex-specific benefits of aspirin in 51,342 women and 44,114 men enrolled in 6 primary prevention trials. This meta-analysis included the Women's Health Study and 5 older RCTs that were published prior to our search dates but were part of the previous 2002 USPSTF review: the British Male Doctors' trial (9), the Physicians Health Study (10), the Thrombosis Prevention Trial (11), the Hypertension Optimal Treatment trial (12), and the Primary Prevention Project (13). The Table lists the trial characteristics included in the Berger meta-analysis. Aspirin use in women was associated with statistically significant reductions in cardiovascular events (odds ratio [OR], 0.88; [CI, 0.79 to 0.99]) and ischemic strokes (OR, 0.76[CI, 0.63 to 0.93]); no statistically significant benefit was found in the reduction of myocardial infarctions or cardiovascular mortality. In men, aspirin use was associated with a statistically significant reduction in cardiovascular events (OR, 0.86 [CI, 0.78 to -0.94]) and in myocardial infarction (OR, 0.68 [CI, 0.54 to 0.86]); no statistically significant benefit was found in the reduction of ischemic stroke or cardiovascular mortality. Total mortality was not significantly reduced by aspirin use in men or women. We rated the Berger study as good quality because of its comprehensive sources, use of established quality-rating criteria, recency, relevance, and the validity of its conclusions.

Table 1 Summary of primary prevention trials in the meta-analysis by Berger and Colleagues

Variable | BMD(9) | PHS(10) | TPT(11) | HOT(12) | PPP(13) | WHS(4)
Publication Date | 1988 | 1989 | 1998 | 1998 | 2001 | 2005
Location | United Kingdom | United States | United Kingdom | Worldwide | Italy | United States
Sample | Male physicians | Male physicians | Men at high risk for heart disease | Men and women with diastolic blood pressure 100 to 115 mm Hg | Men and women with > 1 risk cardiovascular risk factor | Female health professionals
Patients n | 5,139 | 22,071 | 5,085 | 18,790 | 4,495 | 39,876
Women, % | 0 | 0 | 0 | 47 | 58 | 100
Age, y | < 60 (46.9%) 60–69 (39.3%) 70–79 (13.9%) | Mean, 53 (range 40–84) | Mean, 57.5 (range 45–69) | Mean, 61.5 (range 50–80) | < 60 (29%) 60–69 (45%) 70–79 (24%) | Mean, 54.6 45–54 (60.2%) 55–64 (29.5%) ≥ 65 (10.3%)
Mean Duration of Therapy, y ^a^ | 5.8 | 5 | 6.8 | 3.8 | 3.6 | 10.1
Aspirin Dosage | 500 mg daily | 325 mg every other day | 75 mg daily (controlled release) | 75 mg daily | 100 mg daily | 100 mg every other day
Additional Therapies | None | Beta-carotene (50% of patients) | Warfarin^b^ | Felodipine with or without ACE inhibitor or beta blocker | Vitamin E (300 mg every day) | Vitamin E (600 IU every other day); beta-carotene (discontinued after 22.8 months)
Control | No placebo | Placebo | Placebo | Placebo | No placebo | Placebo
Blinding | Open-label | Double-blind | Double-blind | Double-blind | Open-Label | Double-blind
Adjudication | Cardiologist or neurologist blinded to treatment reviewed reported myocardial infarctions, strokes, and TIAs and classified as definite, probable or doubtful. | End points committee of physicians including 2 internists, 1 cardiologist and 1 neurologist, all blinded. | Research nurse annually searched notes for possible end points whether or not the man was still taking trial treatment. Office of National Statistics provided information on end points for men who had moved away from their GP. | Verification of all reported events by the blinded Independent Clinical Event Committee | End points assured by ad hoc committee | Medical records reviewed by blinded end-points committee of physicians.
Quality | Fair * | Good * | Good * | Good * | Fair * | Good

a Values given are means, except for the TPT value which is a median

b Data for patients on Warfarin not included in this table

* Quality rating from a USPSTF review conducted in 2002.

ACE = angiotensin-converting enzyme; BMD = British Male Doctors' Trial; GP = general practitioner; HOT = Hypertension Optimal Treatment trial; PHS = Physicians' Health Study; TIA = transient ischemic attack; TPT = Thrombosis Prevention Trial; PPP = Primary Prevention Project; WHS = Women's Health Study

New evidence about whether specific subpopulations benefit from aspirin use to a greater or lesser extent than the general population is limited to 3 subgroup analyses of RCTs: the Women's Health Study (4) and two subanalyses of RCTs whose original report was published before the dates of our search (14, 15). We have therefore not included the original RCT reports in this review. No consistent evidence from recent studies indicates whether subpopulations may benefit to a greater or lesser extent than the general population. The Women's Health Study performed subgroup analyses by smoking status and age and reported a greater benefit in the group of former and never smokers compared to current smokers, who had a greater reduction in risk for ischemic strokes, and among women 65 years of age or older, who had a greater reduction in the risk for major cardiovascular events, ischemic strokes, and myocardial infarctions (RR for myocardial infarction, 0.66 [CI, 0.44 to 0.97]). A fair quality subgroup analysis of the Hypertension Optimal Treatment study (14) reported a greater than average reduction in myocardial infarctions among subgroups of aspirin users with the following: systolic blood pressure 180 mm Hg or higher, systolic blood pressure 160 to 179 mm Hg, diastolic blood pressure 107 mm Hg or higher, diastolic blood pressure 104 to 106 mm Hg, or serum creatinine greater than 115 μmol/L (>1.3 mg/dL). Methodologic issues—most important, the performance of subanalyses on groups not considered in the randomization process—led to a fair-quality rating. Finally, a fair-quality subgroup analysis of the larger, previously published Primary Prevention Project (15) reported no benefit of aspirin in the reduction of any cardiovascular end points among diabetic patients (hazard ratio for the main combined cardiovascular end point, 0.9 [CI, 0.49 to 1.67]). The results of this study are difficult to interpret because a large number of participants had crossed over to the other group by the end of the trial: 28% of diabetic patients in the aspirin group had discontinued use of the medication, and 12% of diabetics in the control group were taking aspirin. We assigned the study a fair quality rating because the crossover rate was high and the original randomization process did not seem to account for the presence or absence of diabetes mellitus.

## Key Question 2. Does aspirin use in women and men increase gastrointestinal bleeding or hemorrhagic strokes?

New evidence on the harms of aspirin for the primary prevention of CVD events consistently shows that aspirin increases the risk for major bleeding events, primarily gastrointestinal bleeding, in men and women. Limited new evidence suggests that hemorrhagic strokes are statistically significantly increased among men but not increased in women. Four studies provided information on the harms of aspirin for this key question.

The Women's Health Study (4) report that serious gastrointestinal bleeds (requiring transfusion) were more common in the women assigned to the aspirin group (RR, 1.40 [CI. 1.07 to 1.83]). Five women died in the study because of gastrointestinal bleeding, 3 in the placebo group and 2 in the aspirin group. In addition to serious gastrointestinal bleeds, episodes of peptic ulcer, self-reported hematuria, easy bruising, and epistaxis were statistically significantly more common in the group of women randomized to aspirin than in the women randomized to placebo. Increases in hemorrhagic strokes were not statistically significant in the aspirin group (RR, 1.24 (CI 0.82 to 1.87]). The meta-analysis of RCTs discussed above for the key question on benefits reported adverse events with aspirin use in the primary prevention of cardiovascular events in 51,342 women and 44,114 men.(8) Major bleeding events occurred in 301 women (OR, 1.68 [CI 1.13 to 2.52]) and 288 men (OR, 1.72 [CI 1.35 to 2.20]). The odds of hemorrhagic strokes were not significantly increased in women but were significantly increased in men (OR, 1.69 [CI 1.04 to 2.73]).

New evidence as to whether specific subpopulations are harmed to a greater or lesser extent than the general population is limited to two subgroup analyses of previously published RCTs. The subgroup analysis of the Hypertension Optimal Treatment study (14) reported that bleeding events did not differ by blood pressure at baseline. The Sacco subgroup analysis of data from the Primary Prevention Project trial on diabetic patients (15) reported 10 bleeding episodes in the aspirin group and 1 in the control group; no intracranial hemorrhages occurred during the study in either group.