# Methods

## Data Sources and Searches

For evidence on the benefits of aspirin for the primary prevention of CVD events (KQ1), we performed a literature search in PubMed using the following MeSH terms: “aspirin” and “cardiovascular diseases.” For evidence on the harms of aspirin for the primary prevention of CVD events (KQ2), we used the following MeSH terms: “aspirin,” “cardiovascular diseases,” “gastrointestinal hemorrhage,” and “cerebral hemorrhage.” We searched for studies published between January 1, 2001 and August 28, 2008. The literature search was limited to English language studies, human studies, non-pregnant adults, and the following study types for benefits: RCT, meta-analysis, and systematic review. For evidence on harms we limited the search to the following study types: RCT, case control, meta-analysis, and systematic review. In addition to the literature search, we looked for other relevant studies in the Cochrane database and through the examination of reference lists from included and other important articles and through consultation with experts.

## Study Selection

Two reviewers independently reviewed the titles, abstracts, and full articles and selected articles on the basis of predefined inclusion criteria. Disagreements on inclusion were resolved by consensus or the involvement of a third reviewer if necessary. In general, we included studies that met the following criteria: 1) evaluated aspirin versus control for the primary prevention of cardiovascular disease events in adults; 2) study population comprised only subjects with a history of CVD or at very high risk for CVD (e.g., patients with atrial fibrillation); 3) study population was generalizable to the United States primary care population; 4) risk estimates for 1 of the following outcomes were calculated: myocardial infarction, stroke, death from myocardial infarction or stroke, all-cause death for benefits; and gastrointestinal bleeding, serious bleeding episodes, and hemorrhagic stroke, cerebral hemorrhage for harms. We accepted studies that included subjects with a history of CVD or subjects at very high risk for CVD, but only if those studies reported separate results for subjects without a history of CVD or not at very high risk for CVD.

## Data Extraction and Quality Assessment

Two reviewers independently abstracted and quality-rated the included articles. We extracted the following data from the studies: geographic location, duration of therapy, proportion of female subjects, dosage, control, blinding, outcome adjudication, additional therapies, demographics, and effect estimates on the previously listed outcomes. We evaluated the quality of the individual studies using previously published USPSTF criteria on internal and external validity (Appendix Table). (5-7) We evaluated RCTs on adequacy of randomization; maintenance of similar groups (includes attrition, crossovers, adherence, contamination); loss to follow-up; equality, reliability, and validity of measurements; clarity of intervention definitions; and appropriateness of outcomes. We evaluated systematic reviews on comprehensiveness of sources considered, search strategy used, explicit selection criteria, standard appraisal of included studies, validity of conclusions, recency, and relevance. We excluded studies of poor quality. We determined generalizability of study sample to the United States by consensus of 3 reviewers after discussions with the USPSTF on similarities between the healthcare system in the study country and that of the United States. Considerations about whether a population would be similar to the U.S. population include the baseline risk of cardiovascular disease, general health status of the population, and the availability of acute medical care and treatment in a health system with available tertiary care centers.

## Data Synthesis

We synthesized the studies qualitatively and organized them by key question. We did not synthesize quantitatively because of the availability of a good quality meta-analysis by Berger and colleagues. (8) We discuss the results of this meta-analysis in the Results section.

## Role of the Funding Source

The general work of the USPSTF is supported by the Agency for Healthcare Research and Quality. This specific review did not receive separate funding.