# References

1 Rager EL, Bridgeford EP, Ollila DW. Cutaneous melanoma: update on prevention, screening, diagnosis, and treatment. Am Fam Physician. 2005;72(2):269-76. [pmid: 16050450].
2 Garner KL, Rodney WM. Basal and squamous cell carcinoma. Prim Care. 2000;27(2):447-58. [pmid: 10815054].
3 Jemal A, Clegg LX, Ward E, et al. Annual report to the nation on the status of cancer, 1975-2001, with a special feature regarding survival. Cancer. 2004;101(1):3-27. [pmid: 15221985].
4 Diepgen TL, Mahler V. The epidemiology of skin cancer. Br J Dermatol. 2002;146(Suppl 61):1-6. [pmid: 11966724].
5 Wong CS, Strange RC, Lear JT. Basal cell carcinoma. Bmj. 2003;327(7418):794-8. [pmid: 14525881].
6 Raasch BA, Buettner PG, Garbe C. Basal cell carcinoma: histological classification and body-site distribution. Br J Dermatol. 2006;155(2):401-7. [pmid: 16882181].
7 Lo WL, Kao SY, Chi LY, Wong YK, Chang RC. Outcomes of oral squamous cell carcinoma in Taiwan after surgical therapy: factors affecting survival. J Oral Maxillofac Surg. 2003;61(7):751-8. [pmid: 12856245].
8 Kuijpers DI, Thissen MR, Neumann MH. Basal cell carcinoma: treatment options and prognosis, a scientific approach to a common malignancy. Am J Clin Dermatol. 2002;3(4):247-59. [pmid: 12010070].
9 Geller AC, Swetter SM, Brooks K, Demierre MF, Yaroch AL. Screening, early detection, and trends for melanoma: current status (2000-2006) and future directions. J Am Acad Dermatol. 2007;57(4):555-72. quiz 73–6. [pmid: 17870429].
10 Dinehart S. Metastases from squamous cell carcinoma of the skin and lip. J Am Acad Dermatol. 1989;21:241-8. [pmid: 2768574].
11 Weinberg AS, Ogle CA, Shim EK. Metastatic cutaneous squamous cell carcinoma: an update. Dermatol Surg. 2007;33(8):885-99. [pmid: 17661931].
12 MacKie RM. Long-term health risk to the skin of ultraviolet radiation. Prog Biophys Mol Biol. 2006;92(1):92-6. [pmid: 16616325].
13 Tropy J. Melanoma. JAMA. 2004;292(22):2800. [pmid: 15585741].
14 Edwards BK, Brown ML, Wingo PA, et al. Annual report to the nation on the status of cancer, 1975-2002, featuring population-based trends in cancer treatment. J Natl Cancer Inst. 2005;97(19):1407-27. [pmid: 16204691].
15 Ries LAG MD, Krapcho M, Stinchcomb DG, Howlader N, Horner MJ, Mariotto A, Miller BA, Feuer EJ, Altekruse SF, Lewis DR, Clegg L, Eisner MP, Reichman M, Edwards BK (eds). SEER Cancer Statistics Review, 1975-2005 Bethesda, MD: National Cancer Institute; 2008.
16 Jemal A, Siegel R, Ward E, et al. Cancer statistics, 2008. CA Cancer J Clin. 2008;58(2):71-96. [pmid: 18287387].
17 Welch HG, Woloshin S, Schwartz LM. Skin biopsy rates and incidence of melanoma: population based ecological study. BMJ-Epub. 2005:1–4.
18 Kefford R, Bishop JN, Tucker M, et al. Genetic testing for melanoma. Lancet Oncol. 2002;3(11):653-4. [pmid: 12424065].
19 Marks R. Epidemiology of melanoma. Clin Exp Dermatol. 2000;25(6):459-63. [pmid: 11044179].
20 Meyskens FL Jr., Ransohoff DF. Predicting risk for the appearance of melanoma. J Clin Oncol. 2006;24(22):3522-3. [pmid: 16728487].
21 U. S. Preventive Services Task Force. Screening for skin cancer: recommendations and rationale. Am J Prev Med. 2001;20(3 Suppl):44-6. [pmid: 11306231].
22 Helfand M, Mahon SM, Eden KB, Frame PS, Orleans CT. Screening for skin cancer. Am J Prev Med. 2001;20(3 Suppl):47-58. [pmid: 11306232].
23 Chen SC, Bravata DM, Weil E, Olkin I. A comparison of dermatologists' and primary care physicians' accuracy in diagnosing melanoma: a systematic review. Arch Dermatol. 2001;137(12):1627-34. [pmid: 11735713].
24 Berwick M, Begg CB, Fine JA, Roush GC, Barnhill RL. Screening for cutaneous melanoma by skin self-examination. J Natl Cancer Inst. 1996;88(1):17-23. [pmid: 8847720].
25 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
26 Berwick M, Armstrong BK, Ben-Porat L, et al. Sun exposure and mortality from melanoma. J Natl Cancer Inst. 2005;97(3):195-9. [pmid: 15687362].
27 Ries LAG, Eisner MP, Kosary CL, et al. Surveillance, Epidemiology, and End Results (SEER) Program (www.seer.cancer.gov) SEER*Stat Database: Incidence - SEER 9 Regs Public-Use, Nov 2004 Sub (1973-2002): National Cancer Institute, DCCPS, Surveillance Research Program, Cancer Statistics Branch released April 2005, based on the November 2004 submission.
28 Farmer ER, Gonin R, Hanna MP. Discordance in the histopathologic diagnosis of melanoma and melanocytic nevi between expert pathologists. Hum Pathol. 1996;27(6):528-31. [pmid: 8666360].
29 Corona R, Mele A, Amini M, et al. Interobserver variability on the histopathologic diagnosis of cutaneous melanoma and other pigmented skin lesions. J Clin Oncol. 1996;14(4):1218-23. [pmid: 8648377].
30 Brochez L, Verhaeghe E, Bleyen L, Naeyaert JM. Diagnostic ability of general practitioners and dermatologists in discriminating pigmented skin lesions. J Am Acad Dermatol. 2001;44(6):979-86. [pmid: 11369910].
31 Carli P, De Giorgi V, Crocetti E, Caldini L, Ressel C, Giannotti B. Diagnostic and referral accuracy of family doctors in melanoma screening: effect of a short formal training. Eur J Cancer Prev. 2005;14(1):51-5. [pmid: 15677895].
32 de Gannes GC, J I, Martinka M, Crawford RI, Rivers JK. Early detection of skin cancer by family physicians: A pilot project. J Cutan Med Surg. 2004;8(2):103-09. [pmid: 15037942].
33 Aitken JF, Janda M, Elwood M, Youl PH, Ring IT, Lowe JB. Clinical outcomes from skin screening clinics within a community-based melanoma screening program. J Am Acad Dermatol. 2006;54(1):105-14. [pmid: 16384764].
34 Oliveria SA, Chau D, Christos PJ, Charles CA, Mushlin AI, Halpern AC. Diagnostic accuracy of patients in performing skin self-examination and the impact of photography. Arch Dermatol. 2004;140(1):57-62. [pmid: 14732661].
35 Muhn CY, From L, Glied M. Detection of artificial changes in mole size by skin self-examination. J Am Acad Dermatol. 2000;42(5 Pt 1):754-9. [pmid: 10775850].
36 Branstrom R, Hedblad MA, Krakau I, Ullen H. Laypersons' perceptual discrimination of pigmented skin lesions. J Am Acad Dermatol. 2002;46(5):667-73. [pmid: 12004305].
37 Melia J, Moss S, Coleman D, et al. The relation between mortality from malignant melanoma and early detection in the Cancer Research Campaign Mole Watcher Study. Br J Cancer. 2001;85(6):803-07. [pmid: 11556828].
38 Geller AC, Zhang Z, Sober AJ, et al. The first 15 years of the American Academy of Dermatology Skin Cancer Screening Programs: 1985-1999. J Am Acad Dermatol. 2003;48:34-41. [pmid: 12522368].
39 McPherson M, Elwood M, English DR, Baade PD, Youl PH, Aitken JF. Presentation and detection of invasive melanoma in a high-risk population. J Am Acad Dermatol. 2006;54(5):783-92. [pmid: 16635658].
40 Brady MS, Oliveria SA, Christos PJ, et al. Patterns of detection in patients with cutaneous melanoma. Cancer. 2000;89(2):342-7. [pmid: 10918164].
41 Carli P, De Giorgi V, Palli D, et al. Self-detected cutaneous melanomas in Italian patients. Clin Exp Dermatol. 2004;29(6):593-6. [pmid: 15550129].
42 Carli P, De Giorgi V, Palli D, et al. Dermatologist detection and skin self-examination are associated with thinner melanomas: results from a survey of the Italian Multidisciplinary Group on Melanoma. Arch Dermatol. 2003;139(5):607-12. [pmid: 12756097].
43 Epstein DS LJ, L J, Gruber SB, Mofid M, Koch SE. Is physician detection associated with thinner melanomas. JAMA. 1999;281(7):640-43. [pmid: 10029126].
44 Elwood JM. Screening for melanoma and options for its evaluation [see comment]. J Med Screen. 1994;1(1):22-38. [pmid: 8790483].
45 Aitken JF, Elwood JM, Lowe JB, Firman DW, Balanda KP, Ring IT. A randomised trial of population screening for melanoma. J Med Screen. 2002;9(1):33-7. [pmid: 11943795].
46 Cho E, Rosner BA, Feskanich D, Colditz GA. Risk factors and individual probabilities of melanoma for whites. J Clin Oncol. 2005;23(12):2669-75. [pmid: 15837981].
47 Goldstein A, Tucker M. Genetic Predisposition to Cancer London: Edward Arnold Publishers; 2001. (Eeles R, Easton D, Eng C, Ponder B, eds. Familial Melanoma and its Management).
48 Fraser M, Goldstein A, Tucker M. Genetic Testing for Inherited Predisposition to Melanoma: Has the Time Come?. J Drugs Deratol. 2004;3(1):93-95.
49 Goldstein AM, Tucker MA. Genetic Epidemioogy of Cutaneous Melanoma. Arch Dermatol. 2001;137(11):1493-96. [pmid: 11708953].
50 Kefford RF, Bishop JA, Bergman W, Tucker M. Counseling and DNA Testing for Individuals Perceived to be Genetically Predisposed to Melanoma: A consensus Statement of the Melanoma Genetics Consortium. J Clin Oncol. 1999;17(10):3245-51. [pmid: 10506626].