# Discussion

Skin cancer is the most commonly diagnosed cancer. Most of the cases of skin cancer are BCC and SCC. Melanoma, while rarer, is a more common cause of significant morbidity and mortality. SEER data suggests that the incidence of early-stage (see Figure 1 and 2) melanoma is increasing, likely resulting from increased screening but there does not seem to be a resultant decrease in late stage diagnosis or mortality that one would expect if screening were effective. As displayed in Figure 2, the age-adjusted melanoma incidence increased from 12.7 per 100,000 to 18.7 per 1000,000 in 2001; while the age-adjusted melanoma mortality has not changed appreciably, 2.6 per 100,000 in 1985 to 2.7 per 100,000 in 2001. The proportion of melanomas diagnosed in the in-situ stage, as shown in Figure 3, more than tripled between 1978 and 1998, 9.5% and 35.5%, respectively.(27)

Figure 2. Melanoma incidence and mortality rate s in the U.S., 1975-2001

Figure 3. Proportion of melanoma cases by histologic stage in the U.S., 1973-1998

The overall evidence to support the benefits of a screening examination by a physician or patient in reducing morbidity and mortality is poor. We reviewed one fair quality case-control study that had been previously identified in the 2001 report for the USPSTF. We found no new studies on the benefits of screening that met our inclusion/exclusion criteria and were of appropriate quality.

## Accuracy of Screening

Accuracy of screening is an important link in the chain of evidence linking screening in asymptomatic persons with improved health outcomes. There is limited and inconsistent evidence for the accuracy of screening with a whole body examination by physicians or by patients. A recent systematic review using pictures of lesions reported a sensitivity that ranged from 42% to 100% and a specificity of 98%.{Chen, 2001 #178} The same systematic review reported a referral/biopsy sensitivity with a range of 70%–91% and a specificity with a range of 51%–87%. Studies on the accuracy of SSE reported sensitivity and specificity that ranged from 58–75% and 62–98%, respectively. The studies in physicians evaluated the accuracy of diagnosing pigmented lesions, not a screening examination, and many of the studies on self-examination were performed in selected patient populations. Therefore, these results may not be generalizable to a screening examination in the general population. In addition to the accuracy of a physician or patient examination there is the uncertainty of the pathologist's reading of the biopsy specimen. There is some evidence that there is moderate disagreement among pathologists in reading skin biopsies. (28,29)

Several studies on diagnostic and referral accuracy of family physicians and general practitioners have been published since 2001; these studies evaluated accuracy before and after educational interventions and generally concluded that educational interventions improve the diagnostic accuracy of skin cancer examinations. A study from Belgium evaluated the diagnostic ability of 160 general practitioners (GPs), using color slides, before and after an educational course. Before the course, sensitivity in GPs was 72% and specificity was 71%; sensitivity and specificity after the course was 84% and 70%, respectively. Before the course GPs correctly identified the melanoma cases in approximately 50% of the cases; after the course the proportion correct increased to 76%.(30) A similar study from Italy evaluated the diagnostic accuracy of 41 family doctors using photographs of lesions before and after a formal training session. In addition, this study asked family doctors whether they would refer to a dermatologist for each lesion. Prior to the training, family doctors were correct in diagnosing 47% of melanomas and planned to refer 96% of the melanoma lesions. After the training, family doctors correctly diagnosed 76% of melanomas. While family doctors' intention to refer melanoma cases did not significantly change, their intention to refer the benign lesions decreased.(31)

In a study of family physicians, an educational video on skin cancer was given to a random sample of 52 family physicians. Physicians in the intervention and control groups were scored on their knowledge about skin cancer. There was no statistical difference in percent of malignant lesions biopsied between the intervention and control groups, either before or after the video instruction.(32)

A more recent community-based, randomized controlled trial of screening in Australia involving 16,383 whole-body skin examinations reported the specificity and PPV of screening by a PCP for melanoma as 86% and 2.5%, respectively. The overall PPV for all types of skin cancer was 29%.(33) However, the researchers did not follow the subjects with negative results, and therefore could not report the number of true negatives or true specificity.

Three studies have been published that evaluated the accuracy of skin self-examination (SSE). They generally showed variable specificity and sensitivity that was higher with greater size increases in lesions and higher with the use of photographs. Two of these studies assessed the accuracy, after artificial change, in the study subjects' reports of the number or appearance of moles; and one study evaluated the accuracy of SSE before and after education about the ABCD criteria. In one study, 50 adult patients with dysplastic nevi seen at the Memorial Sloan-Kettering Center in New York were photographed after performing a SSE, and the photographs were given to the patients. The number and appearance of moles were altered using cosmetic eyeliner. Patients were then asked to perform SSE with and without access to the photographs; patients were asked to identify new moles or moles that had changed in appearance (including size). Without photographs, the sensitivity for the identification of new and changed moles was 60% and the specificity was 96%; the sensitivity and specificity increased to 72% and 98%, respectively, when subjects had access to the photographs.(34)

A study of 210 patients at high risk for melanoma who attended the Pigmented Lesion Clinic in Toronto evaluated whether the patients could detect a change in size of their moles. These patients had been previously taught how to do a SSE and had been doing a SSE for a year or more. Moles were artificially altered in size by 0, 2, and 4 mm in three different tests and patients were asked to perform a SSE and report whether the size of any of their moles had changed. The sensitivity of the 2 mm and 4 mm change was 58% (95% CI, 49%–68%) and 75% (95% CI, 66%–83%), respectively. The specificity was 62% (95% CI, 53%–72%). The ability to detect changes in size was not statistically significantly related to patient or family history of melanoma, sex, or self-perceived risk.(35)

Non-physicians' ability to classify pigmented lesions as benign or malignant was evaluated in a study of 120 laypersons. Subjects for the study were recruited from the Dermatology and Oncology Departments of a hospital in Sweden. In addition, a randomly selected population-based sample of healthy individuals was included. We report the results of the healthy population sample as this is most relevant when considering screening in the general population. Subjects were given 8 pictures of pigmented lesions and a corresponding plastic sheet with the lesion that they could place on their forearm to simulate the lesion on their skin. Subjects were then asked what they would do if they found the lesion on their skin. The available responses were: “do nothing,” “keep an eye on it,” “show someone else,” “show doctor at next visit,” or “show doctor immediately.” The process was repeated after a short instruction on the ABCD criteria. A scoring system was created to score the appropriateness of action. The score for the healthy population group was 10.37 out of a maximum of 16 before the education, and 13.23 after the education.(36)

In summary, accuracy of screening for skin cancer by physicians and by patients has been studied using several different methods. Many studies measure accuracy through the use of photographs of lesions of known histopathology. Other studies measure accuracy by following the referral patterns and ultimate histopathology of lesions from real patients. There are obvious problems with both of these methods. Using photographs of known lesions may test the accuracy of the diagnostic ability of a physician but does not necessarily assess the accuracy of a full body screening examination. The use of referral patterns and histopathology assumes that a dermatologist's assessment of the need for biopsy and the resultant histopathology constitute the gold standard. Without appropriate follow-up of patients, this method likely underestimates the number of false negatives.

## Screening and Thinness of Melanoma Lesions

We did not find any RCTs that compared screened and unscreened subjects with respect to thickness of melanoma lesions. We identified one study that looked at a screened population to evaluate lesion thickness at detection. A large study of 639,835 subjects who were screened during the American Academy of Dermatology (AAD) Skin Cancer Screening Program from 1985 to 1999 compared the results of the AAD's screening efforts to the SEER registry. In the AAD program, screening examinations were performed by dermatologists and were free and open to the public. The study's authors compared thinness of lesions in those with a diagnosis of melanoma to the thinness of melanoma lesions found in the 1990 SEER registry. There was a higher percentage of lesions <1.50 mm in subjects who had received screening through the AAD program than in the SEER registry, 10% and 2%, respectively (p<0.001).(38) Conclusions are limited because of self-selection in the AAD program, the ecologic nature of the study, and problems with generalizing screening by a dermatologist to screening by primary care clinicians.

A study in Queensland, Australia, reviewed the characteristics of all histologically confirmed first melanomas in residents aged 20–75 years.(39) They found that the rate of thin lesions (<0.75 mm) detected by a physician (81%) was higher than the rate detected by non-physicians (62%).

There is evidence from retrospective studies of patients with diagnosed melanoma that, while most melanoma lesions are first noticed by someone other than a physician, lesions detected by a physician are thinner. A study of 471 newly diagnosed patients with melanoma (1995-1998) in New York found that 57% of patients first detected the melanoma lesion and another 15% were found by someone other than a physician (primarily a spouse). There was a significant association between physician detection and thickness ≤0.75 mm.(40) In an Italian study of 816 consecutive patients diagnosed with melanoma, 57% of lesions were identified by the patient, spouse, or a friend. After adjustment for sex, age, education, nevi, and region of Italy, identification by a dermatologist was associated with significantly thinner melanoma lesions than those identified by others (0.68 mm vs. 0.90 mm). (“Others” included family physicians, other physicians, and the patient, spouse, or a friend.) Interestingly, melanoma lesions in those subjects that performed SSE were also significantly thinner than in those who did not perform skin self-examination (0.77 mm vs. 0.95); however, the definition of SSE was not reported.(41,42) A study of 102 patients seen at the Johns Hopkins Melanoma Center between June 1995 and June 1997 reported that the majority of lesions were detected by the patient. The mean lesion thickness was 0.23 mm for physician-detected and 0.9 mm for self-detected lesions. When compared to self- or other-detected lesions, physician-detected lesions were associated with a higher likelihood of thinner lesions (relative risk of 4.0 (95% CI, 1.08–14.3) for < 0.75 mm versus >0.75 mm).(43)

In summary, there is limited evidence as to whether screening by physicians or by patients identifies lesions that are thinner than those identified in usual care. Older ecological studies reported conflicting results as to the association of thickness of melanoma and screening. There is newer limited evidence from one large study of a self-selected screened population and from retrospective studies that physician examinations and self-examinations identify thinner melanoma lesions. However, the retrospective studies do not report whether the lesions were detected during a screening examination or coincidentally during an examination for other reasons. Therefore, there are problems with using this evidence to generalize about the ability of screening exams to identify thinner lesions in the general public. In addition, the majority of melanoma lesions are identified by the patient, friend, or spouse, and the question remains whether encouraging SSE would identify more lesions or lesions at an earlier stage than are currently being identified by non-physicians.

## Research Gaps

There are several limitations of the literature on screening for skin cancer. A major limitation is the lack of direct evidence linking skin cancer screening to improved health outcomes. Due to the relatively low melanoma-related mortality in the United States, an adequately powered population-based randomized controlled trial of screening demonstrating mortality outcomes would require a study of approximately 800,000 subjects. (22,44) However, the incidence of melanoma and mortality is higher in Australia, and a three-year randomized, controlled trial in 44 Australian communities (n=560,000 adults aged 30 years or more) had been planned by Aitken and colleagues. The intervention included the promotion of screening through skin self examination and physician examination. (45) Unfortunately, the study was only performed in 9 control and 9 intervention communities due to lack of funding. The preliminary results may help inform future recommendations on skin cancer screening.

Other limitations of the literature include a lack of large studies on accuracy of screening in the general population and a lack of information on whether screening in the general population would result in the identification of lesions at an earlier stage than regular care.