# Results

## Does screening in asymptomatic persons with whole body examination by a primary care clinician or by self examination reduce morbidity and mortality from skin cancer?

## Summary of Results

In summary, we found no new evidence on the effectiveness of either skin examination by a physician or skin self examination (SSE) in reducing the morbidity or mortality of skin cancer. One study of fair quality, previously identified in the 2001 Helfand report for the USPSTF, provides limited but not sufficient evidence on the benefit of skin self-exam in the reduction of morbidity and mortality from melanoma.{Helfand et al, 2001, reference #17}

We discuss below two articles by Berwick and colleagues based on the same data, one a case-control study, and the other a follow-up study of the case-control study that reported on the cases. These articles provide non-randomized evidence about the associations between screening (clinical or self-exam) and morbidity and mortality outcomes. The case control study published in 1996 by Berwick et al (24), was previously identified in the 2001 systematic review on screening for skin cancer by Helfand et al for the USPSTF. (22) The second article. published in 2005 by Berwick, analyzed the association of skin self exam (SSE) and mortality from skin cancer. (26)

## Study Characteristics

Data on cases for the 1996 and 2005 Berwick articles (n=650) were obtained from the Connecticut Tumor Registry (CTR), a National Cancer Institute Surveillance Epidemiology and End-Results (SEER) site. Controls (n=549) were identified from the general public through random-digit dialing, and were frequency-matched with respect to age and sex. After obtaining approval from the primary physician for each case, a trained nurse interviewed subjects with a structured questionnaire. The questionnaire included items about demographics, family history, sun exposures, and history of skin cancer screening. In addition to the questionnaire, the nurses performed a limited skin exam to count nevi on the backs and arms. Subjects were followed biannually for a mean of 5.4 years.

Identification of cases was probably fairly complete, because of a state reporting mandate and the research team's active monitoring of dermatopathology laboratories. The response rate for cases and controls was 75% and 70%, respectively. Also, because the research team used several sources to identify deaths of the subjects; the mortality tally was likely to be complete. Limitations of the research design include the following: (1) potential selection bias of cases and controls; (2) lack of information on the initial comparability of the cases and controls; (3) potential recall bias because information on many variables (including the history of any clinical screening) relied on patient report; and (4) lack of information on masking of the nurse or dermatologist to the case status.

## Study Findings

The 1996 Berwick study was a fair quality case-control trial designed to answer the question whether early detection through skin self-examination is associated with a decreased risk of lethal melanoma (defined as organ metastases or death from melanoma). The analyses were adjusted for skin color, sun exposure, number of nevi, family history, tendency to burn, light eye color, light hair color, tendency to freckle before 25 years of age, and ever severely sunburned. Overall, 11% of subjects died from melanoma and 5% from other causes. Fifteen percent of subjects performed self skin-examination (SSE) as measured by a positive response to the question, “Prior to your biopsy (for case subjects), did you ever in your life carefully examine your own skin? By this I mean actually check surfaces of your skin deliberately and purposely?”{Berwick, 1996 #407} Skin self-examination was associated with a reduced risk of melanoma diagnosis (adjusted Odds Ratio (aOR) = 0.66, 95% Confidence Interval (CI) = 0.44–0.99) and a reduced risk of lethal melanoma (aOR = 0.37, 95% CI=0.16–0.84). A comparison of the probability of survival among cases who performed SSE versus those who did not indicates that the benefit from SSE, analyzed using Kaplan-Meier curves, appears to plateau at approximately 3 years, while additional deaths continue to occur among the cases who did not perform SSE. The authors comment that this provides some evidence against significant lead-time bias.

The 2005 Berwick article, that used the data described above, analyzed only the cases and defined the outcome as all deaths due to melanoma. One hundred twelve cases were excluded from the original 650 cases: 26 because of diagnosis from node or organ metastases, 95 with a diagnosis of lentigo maligno melanoma, and one without follow-up. This analysis showed no significant associations between screening exam (SSE or by a physician) and death from melanoma in those with melanoma. On univariate analysis, the hazard ratio (HR) for SSE was 0.6 (95% CI 0.2–1.5) and for physician screening exam was 0.7 (95% CI 0.4–1.3); this is not greatly different from the 1996 analysis that had more subjects and a slightly broader definition of the outcome. The authors report a statistically significant association between “skin awareness” and death from melanoma, HR 0.5 (95% CI, 0.3–0.9) after controlling for other confounders. Skin awareness was defined as a positive response to, “Did you ever think about your skin, how it looked, whether there were any changes, or whether there were any abnormal marks?” (26)