# Methods

## Data Sources and Searches

We searched for English language literature in MEDLINE to identify randomized controlled trials or case-control trials published from June 1, 1999, to August 9, 2005, to answer the key question: Can screening reduce morbidity and mortality from skin cancer? The following MeSH terms were used: skin neoplasms, squamous cell neoplasms, basal cell neoplasms, melanoma, mass screening. In addition to the MEDLINE search, we identified further literature by reviewing reference lists of review articles and editorials and by consulting with experts.

## Study Selection

Two reviewers independently reviewed the title lists, abstracts and full articles. Studies were excluded if: they did not address skin cancer; there were no morbidity or mortality outcomes reported; they were editorials or review articles; there was no control group; or the study population included only subjects with rare skin cancer syndromes. Studies were also excluded if the intervention was not screening with whole body visual examination by a physician or by the patient; studies on interventions not performed in a primary care setting; and studies that focused on interventions to improve diagnostic ability (and not screening). Studies selected by fewer than two reviewers were discussed and selection was based on consensus. A third reviewer was consulted if necessary.

## Data Extraction and Quality Assessment

For all citations that met the eligibility criteria, the full articles were reviewed, abstracted, and quality-rated independently by two reviewers. Consensus about article inclusion, content, and quality was achieved through discussion by the two reviewers; disagreements were resolved by the involvement of a third reviewer. Data on the following items were extracted from the included studies: identification of cases, case definition, selection of controls, comorbidities, sun exposures, demographics of cases and controls, definition of screening examination, exposure to screening, and rates of follow-up, results. Quality evaluations of articles for the key question were performed using standard USPSTF methodology on internal and external validity.(25) We evaluated the quality of RCTs and cohort studies on the following items: initial assembly of comparable groups, maintenance of comparable groups, important differential loss to follow-up or overall high loss to follow-up, measurements (equality, reliability, and validity of outcome measurements), clear definition of the interventions, and appropriateness of outcomes. The quality of case-control studies was evaluated on the following items: accurate ascertainment of cases, nonbiased selection of cases/controls with exclusion criteria applied equally to both, response rate, diagnostic testing procedures applied equally to each group, accurate measurement of exposure applied equally to each group, measurement of exposure accurate and applied equally to each group, and appropriate attention to potential confounding variables.

## Data Synthesis and Analysis

Data from the included studies was synthesized qualitatively in a narrative format.

## Role of the Funding Source

The general work of the USPSTF is supported by the Agency for Healthcare Research and Quality. This specific review did not receive separate funding.