# Introduction

Skin cancer is the most commonly diagnosed cancer in the United States.(1) The majority of skin cancers are non-melanoma cancers, either basal cell cancer or squamous cell cancer.(2) In the United States, melanoma of the skin is the sixth most common type of cancer in white men and women(3). The incidence of both melanoma and non-melanoma skin cancer has been increasing over the last three decades.(4) Several preventive strategies have been proposed by professional organizations, including routine screening.

## Non-melanoma Skin Cancers

Basal cell carcinoma (BCC) is the most common type of skin cancer.(5) The majority of cases are in sun-exposed areas such as the head and neck.(6) BCC lesions grow slowly, but if left untreated they can spread to surrounding tissues; BCC rarely causes death.{Geller, 2007 #626; Kuijpers, 2002 #618} However, due to its high prevalence it results in the expenditure of a large amount of health care resources.

Squamous cell carcinoma (SCC) is most commonly found in fair-skinned individuals with high sun exposure.(4) SCC may arise in areas of previous actinic damage, including actinic keratoses, leukoplakia, and old scars.(2) The reported incidence of metastasis from SCC of the skin ranges from 0.5 to 16% (10,11).

Available evidence suggests that childhood or occupational UV exposure, number of sunburns, actinic keratosis, organ transplantation, fair complexion including light-colored eyes and red or blonde hair, arsenic exposure, and a family history of skin cancer are risk factors for the development of non-melanoma skin cancer.(2, 5, 9, 12)

## Melanoma of the Skin

Melanoma is less common than basal cell and squamous cell carcinoma but is much more likely to metastasize and be fatal.(13) The incidence of melanoma of the skin has steadily increased over the last three decades; the annual percent increase during 1992-2002 was 2.4%.(14) The lifetime risk of being diagnosed with melanoma in white males and white females is 2.56% and 1.73%, respectively, and in black males and black females is 0.07% and 0.09%, respectively.(15) The estimated number of new cases of melanoma of the skin for 2008 is 62,480, 34,950 for men, and 27,530 for women.(16) A study by Welch et al suggests that the increased melanoma incidence is primarily due to increased diagnostic surveillance.(17)

A large number of studies have examined risk factors for the development of melanoma. From these studies, there is evidence that blond and red hair, blue/green eyes, freckles, an inability to tan, a history of frequent sunburns, a family history of melanoma, and an increasing number of nevi and dysplastic nevi are risk factors for the development of melanoma.(1, 18–20)

The lifetime risk of dying from melanoma in white males and white females is 0.43% and 0.23%, respectively, and in black males and black females is 0.04% and 0.04%, respectively.(15) Mortality risk increases with age. During 2001-2005, the mortality rate in white men increased from 5.3 per 100,000 at age 50–54 years to 27.3 per 100,000 at age 80–84. In white women, the mortality rate at age 50–54 years and 80–84 years was 2.8 per 100, 000 and 10.6 per 100,000, respectively.(15) The estimated number of deaths from melanoma of the skin for 2008 is 8,420, 5,400 for men, and 3,020 for women.(15)

The U.S. Preventive Services Task Force (USPSTF) last reviewed screening for skin cancer in 2001 and concluded that there was insufficient evidence to recommend for or against routine screening for skin cancer using a total-body skin examination for the early detection of cutaneous melanoma, basal cell cancer (BCC), or squamous cell cancer (SCC).(21) The USPSTF made this statement after reviewing the available evidence and identifying two major gaps: the lack of good quality evidence that links screening to improved health outcomes and limited information about the ability of primary care providers to perform adequate examinations in the context of usual care. To update its recommendation, the USPSTF determined that an update of the evidence would need to focus on these two issues. (22)

The 2001 review by Helfand et al for the USPSTF identified several studies that evaluated the accuracy of screening of people attending screening programs. Only one study followed subjects “to determine the false negative rate of a screening skin examination.”(22) This study reported sensitivity and specificity of 94% and 98%, respectively. A well-designed study that included 63 Australian general practitioners (GPs) found a sensitivity of 72% and a positive predictive value (PPV) of 39% for whole body exam by GPs on live patients for the identification of suspicious lesions.(22) From several reviews on screening accuracy using photographs of lesions, Helfand et al found that dermatologists performed better than non-dermatologists. The overall sensitivity and specificity of the ABCDE criteria (Asymmetry, Border, Color, Diameter, Elevation/ Enlargement), in one review that evaluated studies of several methods and several types of physicians, was 50–97% and 96–99% respectively. In another review, internal medicine physicians were correct in identifying 52% of skin cancers (from photographs), family medicine physicians were correct in 70% of the cases, and dermatologists in 93% of the cases.

In 2001, a new systematic review concluded that sensitivity and specificity varied widely in both dermatologists and primary care physicians (PCPs). The authors reviewed 9 prospective studies that included data on 2,314 PCPs, and assessed the PCPs' ability to correctly diagnose a lesion from a slide or photograph. Six studies were reviewed that evaluated the biopsy/referral accuracy. The range of the sensitivity of the PCPs' diagnosis of melanoma was 42–100%; only one study reported specificity, 98%. The range for sensitivity for PCPs' biopsy or referral decision accuracy was 70–91%; the range for specificity was 51–87%.(23)

The USPSTF reviewed the evidence in 2001 on the association between screening and the identification of thinner lesions because thinness is an identified prognostic factor. The 2001 report by Helfand et al for the USPSTF reported inconsistent results on the association between thickness of melanoma and delay in diagnosis.(22) Berwick (1996) found a non-significant difference in Breslow depth between those who performed skin self examination (SSE) and those who did not perform SSE; the authors did not report the actual depths of the lesions in the two groups.(24) They did find a significant difference in Breslow depth between “rigorous” self-examiners (defined as using a mirror) and those who did not do a SSE (1.09 mm vs. 1.65 mm, p=0.014) Helfand et al reviewed the evidence on stages of cancer found in screening versus usual practice.(22) They found conflicting results from ecological studies in Australia and the United Kingdom (U.K.) that evaluated the thickness of melanomas after public information campaigns.

Based on an analytic framework (Figure 1), the USPSTF determined that this evidence update would focus on a systematic review of the evidence of controlled trials on screening for skin cancer with morbidity and mortality outcomes to answer the Key Question (KQ): Does screening in asymptomatic persons with whole body examination by a primary care clinician or by self examination reduce morbidity and mortality from skin cancer?. In addition, the USPSTF asked for information concerning several contextual questions. The issues for this review that were identified as contextual questions are:

Figure 1. Analytic Framework for Screening for Skin Cancer

CQ1. Can screening with whole body examination by primary care clinicians or by self examination accurately detect skin cancers?

CQ2. Does screening with whole body examination or by self examination detect melanomas at an earlier stage (thinner lesions)?

The information gathered for these questions was not systematically reviewed and is discussed below in the Discussion section.

This review does not include evidence on counseling for skin cancer. The USPSTF has previously reviewed the evidence for counseling; the evidence review and recommendation can be found online at www.preventiveservices.ahrq.gov.