# Appendixes

Appendix A. MEDLINE® Search Strategy

Appendix B. Data Abstraction Forms

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Peer Reviewers

Appendix G. A Summary of Breastfeeding and Maternal and Term-infant Health Outcomes in Developed Countries

Appendix H. Studies not specifically targeting promotion of breastfeeding that reported breastfeeding, maternal, or infant health outcomes

Appendix J. Before-and-After Experimental Studies and Prospective Observational Studies with Concurrent or Historical Controls on Baby Friendly Hospital Initiative