# Appendix J. Before-and-After Experimental Studies and Prospective Observational Studies with Concurrent or Historical Controls on Baby Friendly Hospital Initiative

Study, year Country Design | Mother's Age (yr) Baby's GA (wk) | Outcome Definition | Results | | | | | | | | Applic | Quality
Experimental studies
Cattaneo 2001 Italy Non-randomized, before-after study | Group 1 Age: 29 GA/BW: ≥ 2000 g Group 2 Age: 30 GA/BW: ≥ 2000 g | Exclusive BF: no other foods or fluid Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | | | Exclusive BF at discharge | | Exclusive BF at 3 mo | | Exclusive BF at 6 mo | | Wide | Poor
Cattaneo 2001 Italy Non-randomized, before-after study | Group 1 Age: 29 GA/BW: ≥ 2000 g Group 2 Age: 30 GA/BW: ≥ 2000 g | Exclusive BF: no other foods or fluid Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | Before | After | Before | After | Before | After | | | Wide | Poor
Cattaneo 2001 Italy Non-randomized, before-after study | Group 1 Age: 29 GA/BW: ≥ 2000 g Group 2 Age: 30 GA/BW: ≥ 2000 g | Exclusive BF: no other foods or fluid Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | | | | | | | | | Wide | Poor
Cattaneo 2001 Italy Non-randomized, before-after study | Group 1 Age: 29 GA/BW: ≥ 2000 g Group 2 Age: 30 GA/BW: ≥ 2000 g | Exclusive BF: no other foods or fluid Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | Group 1 | n | 518 | 510 | 506 | 510 | 485 | 366 | Wide | Poor
Cattaneo 2001 Italy Non-randomized, before-after study | Group 1 Age: 29 GA/BW: ≥ 2000 g Group 2 Age: 30 GA/BW: ≥ 2000 g | Exclusive BF: no other foods or fluid Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | | | | | | | | | Wide | Poor
Cattaneo 2001 Italy Non-randomized, before-after study | Group 1 Age: 29 GA/BW: ≥ 2000 g Group 2 Age: 30 GA/BW: ≥ 2000 g | Exclusive BF: no other foods or fluid Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | | 41% | 77% | 20% | 25% | 1% | 1% | | Wide | Poor
Group 2 | n | 464 | 271 | 471 | 280 | 454 | 233
| 23% | 72% | 15% | 45% | 1% | 13%
BF rates adjusted with direct standardization by parity, type of delivery, and birth weight did not differ significantly. In both group, differences before and after training in exclusive BF at discharge, full BF at 3 mo, ever BF at 6 mo were significant (P<0.05)
Gau 2004 Taiwan Non-randomized, before-after study | Age: 31 GA/BW: 38.8 | Exclusive BF: only breast milk from the mother or a wet nurse, or expressed breast milk, and no other liquids or solids | | | 2000 | | 2001 | | 2002 | | Wide | Poor
Gau 2004 Taiwan Non-randomized, before-after study | Age: 31 GA/BW: 38.8 | Exclusive BF: only breast milk from the mother or a wet nurse, or expressed breast milk, and no other liquids or solids | BFHI | Control | BFHI | Control | BFHI | Control | | | Wide | Poor
Gau 2004 Taiwan Non-randomized, before-after study | Age: 31 GA/BW: 38.8 | Exclusive BF: only breast milk from the mother or a wet nurse, or expressed breast milk, and no other liquids or solids | | | | | | | | | Wide | Poor
Gau 2004 Taiwan Non-randomized, before-after study | Age: 31 GA/BW: 38.8 | Exclusive BF: only breast milk from the mother or a wet nurse, or expressed breast milk, and no other liquids or solids | | n | 1339 | 380 | 1144 | 568 | 869 | 313 | Wide | Poor
Gau 2004 Taiwan Non-randomized, before-after study | Age: 31 GA/BW: 38.8 | Exclusive BF: only breast milk from the mother or a wet nurse, or expressed breast milk, and no other liquids or solids | | | | | | | | | Wide | Poor
Exclusive BF rates in hospital | | 34% | 22% | 46% | 23% | 50% | 23%
Exclusive BF 2 mo rate | | 6% | 5% | 8% | 3% | 12% | 0%
Exclusive breastfeeding rate of the BFHI group was higher than that of the control group in hospital, at 2 weeks, 1 and 2 months postpartum (p<0.001). BF rates increased year by year (P<0.001) from 2000 to 2002.
Observational studies
Dulon 2003 Germany Prospective cohort | Age: 91% ≥ 25 GA/BW: ≥ 37 | Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | | | Prevalence of Full BF | | | | | | Narrow | Poor
Dulon 2003 Germany Prospective cohort | Age: 91% ≥ 25 GA/BW: ≥ 37 | Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | At birth | At discharge (5 day) | 2 mo | 4 mo | 6 mo | | | | Narrow | Poor
Dulon 2003 Germany Prospective cohort | Age: 91% ≥ 25 GA/BW: ≥ 37 | Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | | | | | | | | | Narrow | Poor
Dulon 2003 Germany Prospective cohort | Age: 91% ≥ 25 GA/BW: ≥ 37 | Full BF: exclusive and predominant BF (non-nutritive fluids allowed) | Low BF promotion index (≤5) n=814 | | 91.3% | 79.7% | 59.2% | 42.1% | 10.8% | | Narrow | Poor
High BF promotion index (>5) n=673 | | 90.0% | 76.8% | 60.9% | 49.5% | 15.7%
Increased risk of short-term BF in a hospital with low BF promotion index (adjusted OR: 1.24; 95%CI 0.99, 1.55) after controlling for age, education, area of upbringing, hospital size, and geographic location of hospital. Associations of short-term BF with maternal age < 25, low education level, and upbringing in East Germany, were stronger
Schniedrova 2003 Czech Republic Prospective cohort | M: 91% ≥ 25 B: Term, ≥ 2500 g | Ever BF | Duration of exclusive BF in both groups were comparable: BFHI hospitals: 3.9 mo ± 1.92 SD Other hospitals: 3.90 mo ± 1.84 SD 93.5% of infants were BF exclusively at discharge; 23.1% of infants were BF exclusively at 6 mo. No difference in feeding modes between BFHI and other hospitals. | | | | | | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | | | Prevalence of any BF | | | | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | 1 mo | 3 mo | 6 mo | 9 mo | 11 or 12 mo | | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | | | | | | | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | No intervention (1990-93) | n | 2818 | 2818 | 2818 | 2818 | 2818 | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | | | | | | | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | | 68% | 30% | 11% | 6% | 2% | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | | | | | | | | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | BFHI (1994-98) | n | 2257 | 2257 | 2257 | 2257 | 1179 | | Narrow | Poor
Bosnjak 2004 Croatia Retro- & Prospective cohort | nd | Ever BF: at least one meal of BF per day | | | | | | | | | Narrow | Poor
| 87% | 54% | 28% | 15% | 3%
BFHI + postnatal support (1999-2000) | n | 2133 | 2064 | 1805 | 1214 | 921
| 87% | 66% | 49% | 35% | 23%
P between groups | | NS | <0.05 | <0.05 | <0.05 | <0.05
Not full BFHI because mothers received Happy Baby discharge packs.
Broadfoot 2005 Scotland Prospective cohort | nd | nd | | | UK standard award | | | No accreditation | | | Narrow | Poor
Broadfoot 2005 Scotland Prospective cohort | nd | nd | n | | 39,340 | | | 289,453 | | | Narrow | Poor
Broadfoot 2005 Scotland Prospective cohort | nd | nd | BF at 7 days | | 49.4% | | | 42.0% | | | Narrow | Poor
After controlling for deprivation category, maternal age, number of births at hospital, and year of birth, the adjusted odds ratio of BF at 7 day was 1.28 (95%CI 1.24 to 1.31), compared babies born in hospitals with a UK BFHI standard award to those born in hospitals with no Baby Friendly accreditation.