# Appendix H. Studies not specifically targeting promotion of breastfeeding that reported breastfeeding, maternal, or infant health outcomes

Studies not specifically targeting promotion of breastfeeding that reported breastfeeding, maternal, or infant health outcomes

Study/Country N in intervention vs. control | Population | Intervention/Control | Outcome: Intervention vs. control | | | Quality/Applicability/Comments
Breastfeeding | Maternal | Infant
Randomized Controlled Trials
O'Connor 2003 Canada 353 vs. 380 | Low risk mothers, could be discharged within 2 d postpartum | 2 home visits vs. telephone call | BF rate at 6 mo: 59% vs. 54% (site A); 60% vs. 60% (site B) (NS) | | Total no. of health problems at 4 wk: 55% vs. 49% (site A); 51% vs. 60% (site B) (NS) | Fair Wide >20% loss to followup at 6 mo compared to enrollment
Boulvain 2004 Switzerland 228 vs. 231 | Middle income | Short stay (1–2d) with home care vs. normal hospital stay (3–4d) | BF rate at 6 mo: 35% vs. 36% (NS) | Fewer problems with BF at 4 wk (RR 0.64; 95%CI 0.47, 0.87); no difference in depression score at 4 wk (RR 0.79; 95%CI 0.42, 1.5); no diff in SF-12 physical and mental (P=0.42, 0.44) | Readmission rate to hospital first 6 mo: (12% vs. 5%; RR 2.6; 95%CI 1.3, 5.1) | Poor Wide Incomplete and inconsistent data reporting; no baseline maternal morbidity data
Minkovitz 2001 US 729 vs. 683 | 33% Medicaid, 20% Hispanic, 24% African Americans | Healthy Steps vs. no Healthy Steps | Continue to BF between 2 and 4 mo: 55.6% vs. 54% (adj RR 1.15, 95%CI 0.91, 1.45) | | | Fair Wide No details on breastfeeding
Non-randomized comparative study
Johnston 2004 2006 US 232 vs.91 | Well-educated, middle-income | Healthy Steps (with or without prenatal intervention) vs. Usual Care | BF at 3 mo: 91% vs. 76% (RR 1.14; 5%CI1.09, 1.20) Duration >6 mo 82%vs. 64% (P<0.05) | At 3 mo, less mental health symptoms (14.2% vs. 17.5%, adj RR 0.61, 95%CI 0.49, 0.76); less depression (adj β: -0.59; 95%CI -0.98, -0.19), lower proportion with CES-D score > cutoff (6.6% vs. 12.5%; adj RR 0.42; 95%CI 0.25, 0.71) | At 24 mo, language development did not differ between groups. (combining ≥2 words, sometimes/often vs no; adj RR 1.02; 95%CI 0.94, 1.12) | Poor Wide Unclear how group assignments were made