# Appendix G. A Summary of Breastfeeding and Maternal and Term-infant Health Outcomes in Developed Countries

## (Abridged from Evidence Report No. 153: available at http://www.ahrq.gov/clinic/tp/brfouttp.htm)

Nineteen outcomes were analyzed in this review. We screened over 9,000 abstracts. Thirty-two primary studies on infant health outcomes, 43 primary studies on maternal health outcomes, and 28 systematic reviews or meta-analyses that covered approximately 400 individual studies were included.

The association studies of breastfeeding and health outcomes mostly presented results as odds ratios. To facilitate interpretation of the odds ratio, we chose to present these data as a reduction in relative risk, estimated as “(1 - odds ratio) × 100%”, along with the corresponding 95% confidence interval (CI).

We present three overall summary figures below to give the reader a quick overview of the results from the meta-analyses included in this report on the association of breastfeeding with health outcomes. Outcomes that did not have meta-analyses are not listed in these figures. Figure 1 shows term infant health outcomes expressed as odds ratios or risk ratios comparing the different feeding groups; Figure 2 shows the association between exclusive breastfeeding and term infant health outcomes; and Figure 3 shows maternal health outcomes expressed as odds ratios or risk ratios comparing the different feeding groups.

Figure 1. The relationship between breastfeeding and health outcomes in term infants - meta-analysis results

Legend: MA, meta-analysis; AOM, acute otitis media; GI, gastrointestinal; CC, case-control studies; FH, family history; CVD, cardiovascular disease; IHD, ischemic heart disease; DM, diabetes; adj, adjusted

*17 studies in total were included in Norris 1996 meta-analyses. The number of studies per comparison was not reported.

†Four historical cohort studies reported data on the relationship between breastfeeding and both CVD and IHD mortality.

Figure 2. The relationship between exclusive breastfeeding and health outcomes in term infants - meta-analysis results

Legend: MA, meta-analysis; AOM, acute otitis media; FH, family history; Hosp, hospitalization; exclu, exclusive; LRTI, lower respiratory track infection

*18 studies in total were included in Gdalevich 2001 meta-analyses. The number of studies per comparison was not reported.

Figure 3. The relationship between breastfeeding and maternal outcomes - meta-analysis results

Legend: MA, meta-analysis; BC, breast cancer; RR, relative risk; OC, ovarian cancer; adj, adjusted

## Term Infant Outcomes

Acute Otitis Media. Our meta-analysis of five cohort studies (with 6 comparisons) ^1^ – ^5^ of good and moderate methodological quality showed that breastfeeding was associated with a significant reduction in the risk of acute otitis media. Comparing ever breastfeeding with exclusive bottle-feeding, the pooled adjusted odds ratio of AOM was 0.77 (95%CI 0.64 – 0.91). When comparing exclusive breastfeeding with exclusive bottle-feeding, either for more than 3 or 6 months duration, the pooled odds ratio was 0.50 (95%CI 0.36 – 0.70). These results were adjusted for potential confounders like parental smoking and use of day care.

Atopic Dermatitis. One good quality meta-analysis of 18 prospective cohort studies on full term infants reported an odds ratio of 0.58 (95%CI 0.41 – 0.92) in the risk of atopic dermatitis in children with a family history of atopy and exclusively breastfed for at least 3 months compared with those who were breastfed for less than 3 months. ^6^ The meta-analysis did not distinguish between atopic dermatitis of infancy (under 2 years of age) and persistent or new atopic dermatitis at older ages. It has been postulated that the diagnosis of atopic dermatitis in patients younger than 2 years of age could be attributed to infectious etiologies, which may be prevented by breastfeeding. However, a stratified analysis by duration of followup found the summary odds ratio in the group with less than 2 years of followup was 0.74 (95%CI 0.61 – 0.90), whereas the summary odds ratio in the group with 2 or more years of followup was 0.78 (95%CI 0.62 – 0.99).

Gastrointestinal Infections. For non-specific gastroenteritis, one systematic review identified three primary studies that controlled for potential confounders (eg, maternal education, parity, family living standards). ^7^ These studies reported that there was a reduction in the risk of non-specific gastrointestinal infections during the first year of life in breastfed infants from developed countries. But a summary adjusted estimate taking into account potential confounders could not be determined because the studies did not provide usable quantitative data. However, a recent case-control study from England that took into account the role of potential confounders reported that infants who were currently breastfeeding had a reduced risk of non-specific gastroenteritis compared with infants who were currently not breastfeeding (OR 0.36, 95% CI 0.18 to 0.74, P=0.005). The result was adjusted for age, sex, social class, contact with person in and outside household, and other factors. This study also reported that the protective effect of breastfeeding did not persist beyond 2 months after cessation of breastfeeding. ^8^

Lower Respiratory Tract Diseases. A good quality meta-analysis of seven studies reported an overall risk reduction (summary relative risk 0.28, 95% CI 0.14 – 0.54) of hospitalization secondary to lower respiratory tract diseases in infants less than 1 year of age who were exclusively breastfed for 4 months or more compared with those who were formula-fed. ^9^ The results remained consistent after adjustment for potential confounders like smoking and socioeconomic status.

Asthma. A well-performed meta-analysis from 2001 concluded that breastfeeding was associated with a reduction in the risk of developing asthma. ^10^ This association was stronger in those subjects with a positive family history. However, three new primary studies. ^11^ – ^13^ and one followup study ^14^ reported conflicting results. We updated the meta-analysis with three of the studies. ^11,^ ^12,^ ^14^ Our analysis showed that breastfeeding for at least 3 months was associated with a reduced risk of asthma (OR 0.73, 95%CI 0.59 – 0.92) in those subjects without a family history of asthma compared with those who were not breastfed. This association was also found in subjects under 10 years of age with a positive family history of asthma. It is unclear whether this association changes for older children. It should also be noted that the fourth study, ^13^ which did not qualify for inclusion in our new meta-analyses, reported an increase in asthma risk with increased duration of breastfeeding in those subjects with a maternal history of asthma.

Cognitive Development. One well-performed sibling analysis ^15^ and three prospective cohort studies ^15^ – ^17^ of full-term infants, all conducted in developed countries, adjusted their analyses specifically for maternal intelligence. The studies found little or no evidence for an association between breastfeeding in infancy and cognitive performance in childhood. Most of the published studies adjusted their analyses for socioeconomic status and maternal education but not specifically for maternal intelligence. For those studies that reported a significant effect after specific adjustment for maternal intelligence, residual confounding from other factors such as different home environments cannot be ruled out.

Obesity. Findings from three systematic reviews and meta-analyses of good and moderate methodological quality suggest that a history of breastfeeding is associated with a reduction in the risk of obesity in later life. ^18^ – ^20^ The pooled adjusted odds ratio of overweight/obesity comparing ever breastfeeders to never breastfeeders was 0.76 (95%CI 0.67–0.86) and 0.93 (95%CI: 0.88–0.99) in Arenz 2004 ^18^ and Owen 2005 ^20^ meta-analysis, respectively. In Harder 2005 ^19^ meta-analysis, duration of breastfeeding was significantly negatively related to the unadjusted risk of overweight (regression coefficient: 0.94, 95%CI 0.89 – 0.98), and each month of breastfeeding was found to be associated with a four percent decrease in risk (unadjusted OR 0.96/month of breastfeeding, 95%CI 0.94 – 0.98). However, the results from Harder 2005 meta-analysis employed techniques that required the use of crude odds ratios from the primary studies for its summary estimates. Therefore, those estimates may not be accurate because potential confounders could not be accounted for in the analysis. As demonstrated in the sensitivity analyses in both Arenz 2004 and Owen 2005, the magnitude of effects was reduced when more confounders were adjusted for in the analyses. The observed association between breastfeeding and a reduced risk of obesity could also reflect selective reporting and/or publication bias.

Risk of Cardiovascular Diseases. Results from two moderate quality meta-analyses concluded that there was a small reduction of less than 1.5 mm Hg in systolic blood pressures and no more than 0.5 mm Hg in diastolic blood pressures among adults who were breastfed in their infancy compared with those who were formula-fed. ^21,^ ^22^ The association weakened after stratification by study size, suggesting the possibility of bias in the smaller studies.

One meta-analysis of cohort and case-control studies reported that there was a reduction in total and LDL cholesterol levels by 7.0 mg/dL and 7.7 mg/dL, respectively, in adults who were breastfed during infancy compared with those who were not. ^23^ However, these findings were based on data from adults with a wide age range. The analysis did not segregate the data according to gender and potential confounders were not explicitly analyzed. Detailed information (eg, fasting or non-fasting) on the collection of specimen for cholesterol testing was not included. Because of these deficiencies, the correct characterization of a relationship between breastfeeding and adult cholesterol levels cannot be determined at this time.

One meta-analysis found little or no difference in all-cause and cardiovascular mortality between adults who were breastfed during infancy and those who were not. ^24^ There were possible biases and limitations in the studies reviewed, however. Presence of statistical heterogeneity across studies suggests that it may not have been appropriate to combine estimates from individual studies into one summary estimate. Because of these reasons, no definitive conclusion could be drawn regarding the relationship between a history of breastfeeding and cardiovascular mortality.

Type 1 Diabetes. Two meta-analyses of moderate methodological quality reported statistically significant odds ratios of 1.23 (95%CI 1.12 – 1.35) ^25^ and 1.43 (95%CI 1.15 – 1.77), ^26^ respectively, for the risk of type 1 diabetes in subjects exposed to less than 3 months compared with more than 3 months of breastfeeding. In addition, findings from five ^27^ – ^31^ of six ^27^ – ^32^ studies published since the meta-analyses reported similar results. Since case-control studies are prone to recall biases, Norris and Scott compared the odds ratios in studies relied on long-term recall to assess infant diet with studies that did not. ^25^ The results showed that studies using existing infant records to determine breastfeeding initiation and duration failed to show the associations reported in the studies relying on long-term recall for their exposure data. This suggests that subjects with type 1 diabetes were more likely to report shorter duration of breastfeeding than control subjects.

Type 2 Diabetes. Results from a high-quality systematic review and meta-analysis ^33^ of seven studies ^34^ – ^40^ suggest that breastfeeding is associated with a lower risk of type 2 diabetes in later life, compared with formula feeding. Comparing subjects who were ever breastfed to those who were formula-fed, the pooled adjusted odds ratio of type 2 diabetes in later life was 0.61 (95%CI 0.44–0.85). Three studies provided information on important confounders like birth weight, parental diabetes, socioeconomic status, or maternal body size. ^34,^ ^37,^ ^40^ Even though these three studies found that adjustment did not alter the crude estimate, we cannot be completely confident that potential confounding by birth weight and maternal factors has been ruled out for the overall pooled estimate.

Childhood Leukemia. The published studies on childhood acute lymphocytic leukemia (ALL) were equivocal; a good quality meta-analysis ^41^ reported a moderate protective effect from breastfeeding and the other good quality systematic review ^42^ reached the opposite conclusion. We conducted a meta-analysis including only good and fair quality case-control studies identified in the systematic review, since the meta-analysis did not provide methodological quality grading of primary studies. We combined socioeconomic status-adjusted odds ratios of ALL in relation to short- (≤ 6 months) and long- (> 6 months) term breastfeeding from UKCCS ^43^ , CCG study, ^44^ and Dockerty 1999. ^45^ One study was excluded from the analysis because the duration of breastfeeding was not reported. ^46^ The results from our meta-analysis suggest that long-term breastfeeding is associated with a reduction in the risk of ALL (OR 0.81; 95%CI 0.71 – 0.91).

Infant Mortality. One study of moderate methodological quality evaluated the relationship between breastfeeding and infant mortality. ^47^ The study reported a protective effect of breastfeeding in reducing infant mortality after controlling for some of the potential confounders. However, in subgroup analyses of the study, the only statistically significant association reported was between “never breastfed” and Sudden Infant Death Syndrome (SIDS) or the risk of injury-related deaths. Because of the limited data in this area, the relationship between breastfeeding and infant mortality in developed countries remains unclear.

Sudden Infant Death Syndrome (SIDS). Results from the previously published meta-analysis of case-control studies concluded that an overall crude risk of SIDS was twice as great for formula-fed infants compared with breastfed infants. ^48^ The conclusion may be biased because the reported association was not adjusted for potential confounders.

Findings from the four studies published subsequent to the meta-analysis in developed countries concurred with the findings from the meta-analysis. ^49^ – ^53^ All studies reported autopsy-confirmed diagnoses of SIDS and adjusted for potential confounders. However, the definitions of breastfeeding exposure and the time intervals accepted for defining SIDS varied across studies.

We elected to conduct our own meta-analysis using only studies that provided an objective definition of SIDS (autopsy confirmed SIDS among infants 1 week to 1 year of age), clear reporting of breastfeeding data, and outcomes adjusted for important confounders or risk factors (eg, sleeping positions, maternal smoking, and socioeconomic status). Four studies included in the previously published meta-analysis ^54^ – ^57^ and two studies published since 1997 met the eligibility criteria. ^51,^ ^53^ The results from our meta-analysis found that ever breastfeeding was associated with a reduction in both crude and adjusted risk of SIDS (crude OR 0.41; 95%CI (0.28, 0.58), and adjusted OR 0.64; 95%CI (0.51, 0.81), respectively); both estimates were statistically significant with a reduction in SIDS for the ever breastfed infants.

## Maternal Outcomes

Return to Pre-pregnancy Weight. Three moderate quality prospective cohort studies reported less than 1 kg weight change from pre-pregnancy or first trimester to 1 to 2 year postpartum period in mothers who breastfed. ^58^ – ^60^ Results from four moderate quality prospective cohort studies (in five publications) ^61^ – ^65^ showed that the effects of breastfeeding on postpartum weight loss were unclear. Results from all seven studies consistently showed that many factors other than breastfeeding had larger effects on weight retention or postpartum weight loss. Methodological challenges in these studies included the accurate measurement of weight change, adequate control for numerous covariables including the amount of pregnancy weight gain, and quantifying accurately the exclusivity and the duration of breastfeeding.

Maternal Type 2 Diabetes. Two large cohorts from a high quality longitudinal study of 150,000 parous women in the United States examined the relationship between breastfeeding and the risk of maternal type 2 diabetes. ^66^ In parous women without a history of gestational diabetes, each additional year of breastfeeding was associated with a 4 percent (95% CI 1% to 9%) reduced risk of developing type 2 diabetes in the first cohort and a 12 percent (95% CI 6% to 18%) reduced risk in the second cohort. In women with a history of gestational diabetes, breastfeeding had no significant effect on the already increased risk of diabetes. Because only nurses were included in the cohorts, generalization of findings to the rest of the population must be done with care.

Osteoporosis. There is little or no evidence from six moderate quality case-control studies for an association between lifetime breastfeeding duration and the risk of fractures due to osteoporosis. ^67^ – ^72^ In two ^73,^ ^74^ of three ^73^ – ^75^ moderate or good quality prospective cohort studies using bone mineral density as a surrogate for osteoporosis, lactation does not appear to have an effect on long-term changes in bone mineral densities. The third study found a small decrease in the bone mineral contents in the distal radius with increased duration of breastfeeding (correlation coefficient = -0.34, P = 0.015), but no significant changes in bone mineral contents in the femoral neck or the trochanter. ^75^

Postpartum Depression. Four prospective cohort studies of moderate methodological quality reported on the relationship between a history of breastfeeding and postpartum depression. ^76^ – ^79^ None of the studies explicitly screened for depression at baseline before the initiation of breastfeeding and none of them provided detailed data on breastfeeding. Three of the four studies found an association between a history of short duration of breastfeeding or not breastfeeding with postpartum depression. ^77^ – ^79^ The results were adjusted for socio-demographic and obstetric variables. More investigation will be needed to determine the nature of this association. It is plausible that postpartum depression led to early cessation of breastfeeding, as opposed to breastfeeding altering the risk of depression. Both effects might occur concurrently.

Breast Cancer. Two meta-analyses of moderate methodological quality concluded that there was a reduction of breast cancer risk in women who breastfed their infants. ^80,^ ^81^ The reduction in breast cancer risk was 4.3 percent for each year of breastfeeding in one meta-analysis ^81^ and 28 percent for 12 or more months of lifetime breastfeeding in the other. ^80^ In addition, one ^80^ of the two meta-analyses and another systematic review ^82^ reported decreased risk of breast cancer primarily in premenopausal women. Findings from primary studies published after the meta-analyses concurred with the findings from the earlier meta-analyses. These findings suggest that there is an association between breastfeeding and a reduced risk of breast cancer.

Ovarian Cancer. We reviewed 15 case-control studies ^83^ – ^99^ that examined the relationship between breastfeeding and the risk of ovarian cancer, and performed meta-analyses in nine studies ^83,^ ^85,^ ^87^ – ^90,^ ^93^ – ^95,^ ^99^ that adjusted for potential confounders. The overall result from the nine studies showed an association between breastfeeding and a 21 percent (95% CI 9% to 32%) reduction in the risk of ovarian cancer, compared to never breastfeeding. Because not all the studies reported similar comparisons of breastfeeding durations, we had to estimate the comparable risks in five studies. ^85,^ ^87^ – ^90,^ ^99^ Excluding these five studies from the meta-analysis results in loss of statistical significance for this association.

There was indirect evidence for a dose-response relationship between breastfeeding and a reduced risk of ovarian cancer. Breastfeeding of more than 12 months (cumulative duration) was associated with a reduced risk of ovarian cancer, compared to never breastfeeding. However, it must be noted that the 12 months cutoff was arbitrary, and the odds ratios were estimated in half of these studies.

## References

1 Alho OP, Laara, Oja H. How should relative risk estimates for acute otitis media in children aged less than 2 years be perceived?. J Clin Epidemiol. 1996;49(1):9-14. [pmid: 8598517].
2 Duffy LC, Faden H, Wasielewski R, et al. Exclusive breastfeeding protects against bacterial colonization and day care exposure to otitis media. Pediatrics. 1997;100(4):E7. [pmid: 9310540].
3 Duncan B, Ey J, Holberg CJ, et al. Exclusive breast-feeding for at least 4 months protects against otitis media.[see comment]. Pediatrics. 1993;91(5):867-72. [pmid: 8474804].
4 Scariati PD, Grummer-Strawn LM, Fein SB. A longitudinal analysis of infant morbidity and the extent of breastfeeding in the United States. Pediatrics. 1997;99(6):E5. [pmid: 9164801].
5 Teele DW, Klein JO, Rosner B. Epidemiology of otitis media during the first seven years of life in children in greater Boston: a prospective, cohort study. J Infect Dis. 1989;160(1):83-94. [pmid: 2732519].
6 Gdalevich M, Mimouni D, David M, et al. Breast-feeding and the onset of atopic dermatitis in childhood: a systematic review and meta-analysis of prospective studies. J Am Acad Dermatol. 2001;45(4):520-7. [pmid: 11568741].
7 Chien PF, Howie PW. Breast milk and the risk of opportunistic infection in infancy in industrialized and non-industrialized settings. [Review] [75 refs]. Adv Nutr Res. 2001;10:69-104. [pmid: 11795054].
8 Quigley MA, Cumberland P, Cowden JM, et al. How protective is breast feeding against diarrhoeal disease in infants in 1990s England? A case-control study. Arch Dis Child. 2006;91(3):245-50. [pmid: 16308409].
9 Bachrach VR, Schwarz E, Bachrach LR. Breastfeeding and the risk of hospitalization for respiratory disease in infancy: a meta-analysis. Arch Pediatr Adolesc Med. 2003;157(3):237-43. [pmid: 12622672].
10 Gdalevich M, Mimouni D, Mimouni M. Breast-feeding and the risk of bronchial asthma in childhood: a systematic review with meta-analysis of prospective studies. J Pediatr. 2001;139(2):261-6. [pmid: 11487754].
11 Burgess SW, Dakin CJ, O'Callaghan MJ. Breastfeeding does not increase the risk of asthma at 14 years. Pediatrics. 2006;117(4):e787-e792. [pmid: 16585289].
12 Kull I, Almqvist C, Lilja G, et al. Breast-feeding reduces the risk of asthma during the first 4 years of life.[see comment]. J Allergy Clin Immunol. 2004;114(4):755-60. [pmid: 15480312].
13 Sears MR, Greene JM, Willan AR, et al. Long-term relation between breastfeeding and development of atopy and asthma in children and young adults: a longitudinal study.[see comment]. Lancet. 2002;360(9337):901-7. [pmid: 12354471].
14 Wright AL, Holberg CJ, Taussig LM, et al. Factors influencing the relation of infant feeding to asthma and recurrent wheeze in childhood.[see comment]. Thorax. 2001;56(3):192-7. [pmid: 11182011].
15 Der G, Batty D, Deary IJ. Effect of breast feeding on intelligence in children: prospective study, sibling pairs analysis, and meta-analysis. BMJ 2006.
16 Angelsen NK, Vik T, Jacobsen G, et al. Breast feeding and cognitive development at age 1 and 5 years. Arch Dis Child. 2001;85(3):183-8. [pmid: 11517096].
17 Gomez-Sanchiz M, Canete R, Rodero I, et al. Influence of breast-feeding and parental intelligence on cognitive development in the 24-month-old child. Clin Pediatr (Phila). 2004;43(8):753-61. [pmid: 15494884].
18 Arenz S, Ruckerl R, Koletzko B, et al. Breast-feeding and childhood obesity—a systematic review. [Review] [51 refs]. Int J Obes Relat Metab Disord. 2004;28(10):1247-56. [pmid: 15314625].
19 Harder T, Bergmann R, Kallischnigg G, et al. Duration of breastfeeding and risk of overweight: a meta-analysis. Am J Epidemiol. 2005;162(5):397-403. [pmid: 16076830].
20 Owen CG, Martin RM, Whincup PH, et al. Effect of infant feeding on the risk of obesity across the life course: a quantitative review of published evidence. Pediatrics. 2005;115(5):1367-77. [pmid: 15867049].
21 Martin RM, Gunnell D, Smith GD. Breastfeeding in infancy and blood pressure in later life: systematic review and meta-analysis. Am J Epidemiol. 2005;161(1):15-26. [pmid: 15615909].
22 Owen CG, Whincup PH, Gilg JA, et al. Effect of breast feeding in infancy on blood pressure in later life: systematic review and meta-analysis. [Review] [26 refs]. BMJ. 2003;327(7425):1189-95. [pmid: 14630752].
23 Owen CG, Whincup PH, Odoki K, et al. Infant feeding and blood cholesterol: a study in adolescents and a systematic review.[see comment]. [Review] [88 refs]. Pediatrics. 2002;110(3):597-608. [pmid: 12205266].
24 Martin RM, Davey SG, Mangtani P, et al. Breastfeeding and cardiovascular mortality: the Boyd Orr cohort and a systematic review with meta-analysis. [Review] [25 refs]. Eur Heart J. 2004;25(9):778-86. [pmid: 15120889].
25 Norris JM, Scott FW. A meta-analysis of infant diet and insulin-dependent diabetes mellitus: do biases play a role?. Epidemiology. 1996;7(1):87-92. [pmid: 8664407].
26 Gerstein HC. Cow's milk exposure and type I diabetes mellitus. A critical overview of the clinical literature. Diabetes Care. 1994;17(1):13-9. [pmid: 8112184].
27 EURODIAS S. Rapid early growth is associated with increased risk of childhood type 1 diabetes in various European populations. Diabetes Care. 2002;25(10):1755-60. [pmid: 12351473].
28 Jones ME, Swerdlow AJ, Gill LE, et al. Pre-natal and early life risk factors for childhood onset diabetes mellitus: a record linkage study. Int J Epidemiol. 1998;27(3):444-9. [pmid: 9698133].
29 McKinney PA, Parslow R, Gurney KA, et al. Perinatal and neonatal determinants of childhood type 1 diabetes. A case-control study in Yorkshire, U.K. Diabetes Care. 1999;22(6):928-32. [pmid: 10372244].
30 Tai TY, Wang CY, Lin LL, et al. A case-control study on risk factors for Type 1 diabetes in Taipei City. Diabetes Res Clin Pract. 1998;42(3):197-203. [pmid: 9925351].
31 Visalli N, Sebastiani L, Adorisio E, et al. Environmental risk factors for type 1 diabetes in Rome and province. Arch Dis Child. 2003;88(8):695-8. [pmid: 12876166].
32 Meloni T, Marinaro AM, Mannazzu MC, et al. IDDM and early infant feeding. Sardinian case-control study. Diabetes Care 1997;(3):340–2.
33 Owen CG, Martin RM, Whincup PH, et al. Does breastfeeding influence risk of type 2 diabetes in later life? A quantitative analysis of published evidence. Am J Clin Nutr. 2006;84(5):1043-54. [pmid: 17093156].
34 Fall CH, Osmond C, Barker DJ, et al. Fetal and infant growth and cardiovascular risk factors in women. BMJ. 1995;310(6977):428-32. [pmid: 7873947].
35 Martin RM, Ebrahim S, Griffin M, et al. Breastfeeding and atherosclerosis: intima-media thickness and plaques at 65-year follow-up of the Boyd Orr cohort. Arterioscler Thromb Vasc Biol. 2005;25(7):1482-8. [pmid: 15890972].
36 Martin RM, Ben-Shlomo Y, Gunnell D, et al. Breast feeding and cardiovascular disease risk factors, incidence, and mortality: the Caerphilly study. J Epidemiol Community Health. 2005;59(2):121-9. [pmid: 15650143].
37 Pettitt D, Decourten M, Nelson R, et al. Lower prevalence of NIDDM in breast-fed Pima-Indians. Diabetes 44. 1995. A6
38 Ravelli AC, van der Meulen JH, Osmond C, et al. Infant feeding and adult glucose tolerance, lipid profile, blood pressure, and obesity. Arch Dis Child. 2000;82(3):248-52. [pmid: 10685933].
39 Rich-Edwards JW, Stampfer MJ, Manson JE, et al. Breastfeeding during infancy and the risk of cardiovascular disease in adulthood. Epidemiology. 2004;15(5):550-6. [pmid: 15308954].
40 Young TK, Martens PJ, Taback SP, et al. Type 2 diabetes mellitus in children: prenatal and early infancy risk factors among native canadians. Arch Pediatr Adolesc Med. 2002;156(7):651-5. [pmid: 12090830].
41 Kwan ML, Buffler PA, Abrams B, et al. Breastfeeding and the risk of childhood leukemia: a meta-analysis. Public Health Rep. 2004;119(6):521-35. [pmid: 15504444].
42 Guise JM, Austin D, Morris CD. Review of case-control studies related to breastfeeding and reduced risk of childhood leukemia. Pediatrics. 2005;116(5):e724-e731. [pmid: 16263987].
43 VaUCCSI Beral. Breastfeeding and childhood cancer. Br J Cancer. 2001;85(11):1685-94. [pmid: 11742489].
44 Shu XO, Linet MS, Steinbuch M, et al. Breast-feeding and risk of childhood acute leukemia. J Natl Cancer Inst. 1999;91(20):1765-72. [pmid: 10528028].
45 Dockerty JD, Skegg DC, Elwood JM, et al. Infections, vaccinations, and the risk of childhood leukaemia. Br J Cancer. 1999;80(9):1483-9. [pmid: 10424755].
46 Rosenbaum PF, Buck GM, Brecher ML. Early child-care and preschool experiences and the risk of childhood acute lymphoblastic leukemia. Am J Epidemiol. 2000;152(12):1136-44. [pmid: 11130619].
47 Chen A, Rogan WJ. Breastfeeding and the risk of postneonatal death in the United States. Pediatrics. 2004;113(5):e435-e439. [pmid: 15121986].
48 McVea KL, Turner PD, Peppler DK. The role of breastfeeding in sudden infant death syndrome. J Hum Lact. 2000;16(1):13-20. [pmid: 11138219].
49 Findeisen M, Vennemann M, Brinkmann B, et al. German study on sudden infant death (GeSID): design, epidemiological and pathological profile. Int J Legal Med. 2004;118(3):163-9. [pmid: 15042379].
50 Hauck FR, Herman SM, Donovan M, et al. Sleep environment and the risk of sudden infant death syndrome in an urban population: the Chicago Infant Mortality Study. Pediatrics. 2003;111(5 Part 2):1207-14. [pmid: 12728140].
51 Mitchell EA, Tuohy PG, Brunt JM, et al. Risk factors for sudden infant death syndrome following the prevention campaign in New Zealand: a prospective study. Pediatrics. 1997;100(5):835-40. [pmid: 9346984].
52 Schellscheidt J, Ott A, Jorch G. Epidemiological features of sudden infant death after a German intervention campaign in 1992. Eur J Pediatr. 1997;156(8):655-60. [pmid: 9266202].
53 Vennemann MM, Findeisen M, ButterfassBahloul T, et al. Modifiable risk factors for SIDS in Germany: results of GeSID. Acta Paediatrica. 2005;94(6):655-60. [pmid: 16188764].
54 Wennergren G, Alm B, Oyen N, et al. The decline in the incidence of SIDS in Scandinavia and its relation to risk-intervention campaigns. Nordic Epidemiological SIDS Study. Acta Paediatrica. 1997;86(9):963-8. [pmid: 9343276].
55 Brooke H, Gibson A, Tappin D, et al. Case-control study of sudden infant death syndrome in Scotland, 1992-5.[see comment]. BMJ. 1997;314(7093):1516-20. [pmid: 9169398].
56 Mitchell EA, Taylor BJ, Ford RP, et al. Four modifiable and other major risk factors for cot death: the New Zealand study.[see comment]. J Paediatr Child Health. 1992;28:Suppl-8.
57 Fleming PJ, Blair PS, Bacon C, et al. Environment of infants during sleep and risk of the sudden infant death syndrome: results of 1993-5 case-control study for confidential inquiry into stillbirths and deaths in infancy. Confidential Enquiry into Stillbirths and Deaths Regional Coordinators and Researchers.[see comment]. BMJ. 1996;313(7051):191-5. [pmid: 8696193].
58 Sichieri R, Field AE, Rich-Edwards J, et al. Prospective assessment of exclusive breastfeeding in relation to weight change in women. Int J Obes Relat Metab Disord. 2003;27(7):815-20. [pmid: 12821967].
59 Janney CA, Zhang D, Sowers M. Lactation and weight retention. Am J Clin Nutr. 1997;66(5):1116-24. [pmid: 9356528].
60 Olson CM, Strawderman MS, Hinton PS, et al. Gestational weight gain and postpartum behaviors associated with weight change from early pregnancy to 1 y postpartum. Int J Obes Relat Metab Disord. 2003;27(1):117-27. [pmid: 12532163].
61 Ohlin A, Rossner S. Maternal body weight development after pregnancy. Int J Obes. 1990;14(2):159-73. [pmid: 2341224].
62 Ohlin A, Rossner S. Factors related to body weight changes during and after pregnancy: the Stockholm Pregnancy and Weight Development Study. Obes Res. 1996;4(3):271-6. [pmid: 8732961].
63 Brewer MM, Bates MR, Vannoy LP. Postpartum changes in maternal weight and body fat depots in lactating vs nonlactating women. Am J Clin Nutr. 1989;49(2):259-65. [pmid: 2916446].
64 Walker L, Freeland-Graves JH, Milani T, et al. Weight and behavioral and psychosocial factors among ethnically diverse, low-income women after childbirth: II. Trends and correlates. Women Health. 2004;40(2):19-34. [pmid: 15778136].
65 Haiek LN, Kramer MS, Ciampi A, et al. Postpartum weight loss and infant feeding. J Am Board Fam Pract. 2001;14(2):85-94. [pmid: 11314929].
66 Stuebe AM, Rich-Edwards JW, Willett WC, et al. Duration of lactation and incidence of type 2 diabetes. JAMA. 2005;294(20):2601-10. [pmid: 16304074].
67 Alderman BW, Weiss NS, Daling JR, et al. Reproductive history and postmenopausal risk of hip and forearm fracture. Am J Epidemiol. 1986;124(2):262-7. [pmid: 3728442].
68 Chan HH, Lau EM, Woo J, et al. Dietary calcium intake, physical activity and the risk of vertebral fracture in Chinese. Osteoporos Int. 1996;6(3):228-32. [pmid: 8783297].
69 Cumming RG, Klineberg RJ. Breastfeeding and other reproductive factors and the risk of hip fractures in elderly women.[erratum appears in Int J Epidemiol 1993 Oct;22(5):962]. Int J Epidemiol. 1993;22(4):684-91. [pmid: 8225744].
70 Hoffman S, Grisso JA, Kelsey JL, et al. Parity, lactation and hip fracture. Osteoporos Int. 1993;3(4):171-6. [pmid: 8338971].
71 Kreiger N, Kelsey JL, Holford TR, et al. An epidemiologic study of hip fracture in postmenopausal women. Am J Epidemiol. 1982;116(1):141-8. [pmid: 7102649].
72 Michaelsson K, Baron JA, Farahmand BY, et al. Influence of parity and lactation on hip fracture risk. Am J Epidemiol. 2001;153(12):1166-72. [pmid: 11415951].
73 Matsushita H, Kurabayashi T, Tomita M, et al. The effect of multiple pregnancies on lumbar bone mineral density in Japanese women. Calcif Tissue Int. 2002;71(1):10-3. [pmid: 12200655].
74 Sowers MR, Clark MK, Hollis B, et al. Radial bone mineral density in pre- and perimenopausal women: a prospective study of rates and risk factors for loss. J Bone Miner Res. 1992;7(6):647-57. [pmid: 1414483].
75 Uusi-Rasi K, Sievanen H, Pasanen M, et al. Association of physical activity and calcium intake with the maintenance of bone mass in premenopausal women. Osteoporos Int. 2002;13(3):211-7. [pmid: 11991440].
76 Chaudron LH, Klein MH, Remington P, et al. Predictors, prodromes and incidence of postpartum depression. J Psychosom Obstet Gynaecol. 2001;22(2):103-12. [pmid: 11446151].
77 Henderson JJ, Evans SF, Straton JA, et al. Impact of postnatal depression on breastfeeding duration.[erratum appears in Birth. 2004 Mar;31(1):76]. Birth. 2003;30(3):175-80. [pmid: 12911800].
78 Warner R, Appleby L, Whitton A, et al. Demographic and obstetric risk factors for postnatal psychiatric morbidity. Br J Psychiatry. 1996;168(5):607-11. [pmid: 8733800].
79 Cooper PJ, Murray L, Stein A. Psychosocial factors associated with the early termination of breast-feeding. J Psychosom Res. 1993;37(2):171-6. [pmid: 8463993].
80 Bernier MO, PluBureau G, Bossard N, et al. Breastfeeding and risk of breast cancer: a metaanalysis of published studies. Hum Reprod Update. 2000;6(4):374-86. [pmid: 10972524].
81 Collaborative Group on Hormonal Factors in Breast Cancer. Breast cancer and breastfeeding: collaborative reanalysis of individual data from 47 epidemiological studies in 30 countries, including 50302 women with breast cancer and 96973 women without the disease.[see comment][comment]. [Review] [68 refs]. Lancet. 2002;360(9328):187-95. [pmid: 12133652].
82 Lipworth L, Bailey LR, Trichopoulos D. History of breast-feeding in relation to breast cancer risk: a review of the epidemiologic literature.[see comment]. [Review] [43 refs]. J Natl Cancer Inst. 2000;92(4):302-12. [pmid: 10675379].
83 Chiaffarino F, Pelucchi C, Negri E, et al. Breastfeeding and the risk of epithelial ovarian cancer in an Italian population. Gynecol Oncol. 2005;98(2):304-8. [pmid: 15975644].
84 Cramer DW, Hutchison GB, Welch WR, et al. Determinants of ovarian cancer risk. I. Reproductive experiences and family history. J Natl Cancer Inst. 1983;71(4):711-6. [pmid: 6578366].
85 Greggi S, Parazzini F, Paratore MP, et al. Risk factors for ovarian cancer in central Italy. Gynecol Oncol. 2000;79(1):50-4. [pmid: 11006030].
86 Gwinn ML, Lee NC, Rhodes PH, et al. Pregnancy, breast feeding, and oral contraceptives and the risk of epithelial ovarian cancer. J Clin Epidemiol. 1990;43(6):559-68. [pmid: 2348208].
87 Hartge P, Schiffman MH, Hoover R, et al. A case-control study of epithelial ovarian cancer. Am J Obstet Gynecol. 1989;161(1):10-6. [pmid: 2750791].
88 Modugno F, Ness RB, Wheeler JE. Reproductive risk factors for epithelial ovarian cancer according to histologic type and invasiveness. Ann Epidemiol 2001;2001 Nov; 11(8):568–74.
89 Ness RB, Grisso JA, Cottreau C, et al. Factors related to inflammation of the ovarian epithelium and risk of ovarian cancer.[see comment]. Epidemiology. 2000;11(2):111-7. [pmid: 11021606].
90 Riman T, Dickman PW, Nilsson S, et al. Risk factors for invasive epithelial ovarian cancer: results from a Swedish case-control study. Am J Epidemiol. 2002;156(4):363-73. [pmid: 12181107].
91 Risch HA, Weiss NS, Lyon JL, et al. Events of reproductive life and the incidence of epithelial ovarian cancer. American Journal of Epidemiology. 1983;117(2):128-39. [pmid: 6681935].
92 Risch HA, Marrett LD, Howe GR. Parity, contraception, infertility, and the risk of epithelial ovarian cancer. Am J Epidemiol. 1994;140(7):585-97. [pmid: 7942759].
93 Siskind V, Green A, Bain C, et al. Breastfeeding, menopause, and epithelial ovarian cancer. Epidemiology. 1997;8(2):188-91. [pmid: 9229212].
94 Titus-Ernstoff L, Perez K, Cramer DW, et al. Menstrual and reproductive factors in relation to ovarian cancer risk. Br J Cancer. 2001;84(5):714-21. [pmid: 11237375].
95 Tung KH, Goodman MT, Wu AH, et al. Reproductive factors and epithelial ovarian cancer risk by histologic type: a multiethnic case-control study. Am J Epidemiol. 2003;158(7):629-38. [pmid: 14507598].
96 Tung KH, Wilkens LR, Wu AH, et al. Effect of anovulation factors on pre- and postmenopausal ovarian cancer risk: revisiting the incessant ovulation hypothesis. Am J Epidemiol. 2005;161(4):321-9. [pmid: 15692075].
97 West RO. Epidemiologic study of malignancies of the ovaries. Cancer. 1966;19(7):1001-7. [pmid: 5939299].
98 Wynder EL, Dodo H, Barber HR. Epidemiology of cancer of the ovary. Cancer. 1969;23(2):352-70. [pmid: 5764976].
99 Yen ML, Yen BL, Bai CH, et al. Risk factors for ovarian cancer in Taiwan: a case-control study in a low-incidence population. Gynecol Oncol. 2003;89(2):318-24. [pmid: 12713998].