# Appendix E. Peer Reviewers

The peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers. The authors gratefully acknowledge the peer reviewers.

- Lori Feldman-Winter, MD, MPH
- Robert Wood Johnson Medical School
- University of Medicine and Dentistry of New Jersey
- Camden, NJ

- Pamela D. Hill, PhD, RN
- College of Nursing
- University of Illinois at Chicago
- Director, Quad Cities Regional Program
- Moline, Illinois

- Ardythe L. Morrow, PhD, MSc
- Center for Epidemiology and Biostatistics
- Cincinnati Children's Hospital Medical Center
- Cincinnati, Ohio