# Appendix D. List of Excluded Studies

Breastfeeding in the WHO Multicentre Growth Reference Study. Acta Paediatr Suppl 2006;450:16–26. No control group
Banderali G, Riva E, Scaglioni S, et al. Monitoring breastfeeding rates in Italy. Acta Paediatrica Suppl. Sep. 2003;91(441):6-8. Retrospective design.
Banks JW. Ka'nistenhsera. Teiakotihsnie's. A Native community rekindles the tradition of breastfeeding.[erratum appears in AWHONN Lifelines. 2003 Dec–2004 Jan;7(6):493]. AWHONN Lifelines. Aug. 2003;7(4):340-7. Review. [pmid: 14528591].
Barlow A, Varipatis-Baker E, Speakman K, et al. Home-visiting intervention to improve child care among American Indian adolescent mothers: a randomized trial. Arch Pediar & Adolesc Med. Nov. 2006;160(11):1101-7. No interventions.
Bartington S, Griffiths LJ, Tate AR, et al. Are breastfeeding rates higher among mothers delivering in Baby Friendly accredited materrnity units in the UK?. Int J Epidemiol. Oct. 2006;35(5):1178-86. Retrospective design. [pmid: 16926214].
Battersby S. The Worldly Wise project. A different approach to breastfeeding support. Practising Midwife. Jun. 2001;4(6):30-1. No outcome of interest. [pmid: 12026844].
Beake S, McCourt C, Rowan C, et al. Evaluation of the use of health care assistants to support disadvantaged women breastfeeding in the community. Maternal & Child Nutr. Jan. 2005;1(1):32-43. Historical control.
Benis MM. Are pacifiers associated with early weaning from breastfeeding?. Adv Neonatal Care. Oct. 2002;2(5):259-66. Review. [pmid: 12881939].
Binns CW, Scott JA. Using pacifiers: what are breastfeeding mothers doing?. Breastfeeding Review. Jul. 2002;10(2):21-5. Review. [pmid: 12227560].
Black MM, Siegel EH, Abel Y, et al. Home and videotape intervention delays early complementary feeding among adolescent mothers. Pediatrics. May. 2001;107(5):E67. No comparative breastfeeding outcome. [pmid: 11331717].
Britten J, Hoddinott P, McInnes R. Breastfeeding peer support: health service programmes in Scotland. Br J of Midwifery 1916. Jan. 2006;14(1):12-4. No outcome of interest.
Caddy R. The Reading breastfeeding drop-in centre. Practising Midwife. Nov. 2002;5(10):18-22. Observational study; BF rate not reported. [pmid: 12478958].
Campbell MK, Carbone E, Honess-Morreale L, et al. Randomized trial of a tailored nutrition education CD-ROM program for women receiving food assistance. J Nutrition Ed and Behavior. Mar–Apr. 2004;36(2):58-66. No interventions.
Chapman D, Damio G, Young S, et al. Association of degree and timing of exposure to breasfeeding peer counseling services with breastfeeding duration. Advances in Experimental Med & Biol. 2004;554:303-6. In Britton 2006 systematic review.
Chapman DJ. Randomized trial evaluating a unique lactation consultant intervention. J Hum Lactation. Aug. 2006;22(3):362-3. Editorial.
Chapman DJ, Young S, Ferris AM, et al. Impact of breast pumping on lactogenesis stage II after cesarean delivery: a randomized clinical trial. Pediatrics. Jun. 2001;107(6):E94. Abstract. [pmid: 11389292].
Chapman DJ, Damio G, Perez-Escamilla R. Differential response to breastfeeding peer counseling within a low-income, predominantly Latina population. J Hum Lactation. Nov. 2004;20(4):389-96. In Britton 2006 systematic review.
Chapman DJ, Damio G, Young S, et al. Effectiveness of breastfeeding peer counseling in a low-income, predominantly Latina population: a randomized controlled trial. Arch Pediatr & Adolesc Med. Sep. 2004;158(9):897-902. In Britton 2006 systematic review. [pmid: 15351756].
Chatterji P, Brooks-Gunn J. WIC participation, breastfeeding practicess, and well-child care among unmarried, low-income mothers. Am J Public Health. Aug. 2004;94(8):1324-7. Observational study. [pmid: 15284035].
De KM, Blais R, Joubert P, et al. Comparing women's assessment of midwifery and medical care in Quebec, Canada. J Midwifery & Women's Health. Mar. 2001;46(2):60-7. No outcome of interest. [pmid: 11370691].
Dennis CL. Breastfeeding peer support: maternal and volunteer perceptions from a randomized controlled trial. Birth. Sep. 2002;29(3):169-76. In Britton 2006 systematic review. [pmid: 12153647].
Dennis CL, Hodnett E, Gallop R, et al. The effect of peer support on breast-feeding duration among primiparous women: a randomized controlled trial.[see comment]. CMAJ. Jan 8. 2002;166(1):21-8. In Britton 2006 systematic review. [pmid: 11800243].
Di NA, Di LD, Fortes C, et al. Home breastfeeding support by health professionals: findings of a randomized controlled trial in a population of Italian women. Acta Paediatrica. Aug. 2004;93(8):1108-14. In Britton 2006 systematic review. [pmid: 15456204].
Downie J, Rakic V, Juliff D. Enhancing the ability of nurses and midwives to promote breastfeeding: a longitudinal study. Birth Issues. 2002;11(2/3):53-9. No interventions.
Durand M, Labarere J, Brunet E, et al. Evaluation of a training program for healthcare professionals about breast-feeding. Eur J of Obstetr Gynecol, & Reprod Biol. Feb 10. 2003;106(2):134-8. Historical control.
Dykes F. ‘Supply’ and ‘demand’: breastfeeding as labour. Soc Sci & Med. May. 2005;60(10):2283-93. No outcome of interest. [pmid: 15748676].
Escobar GJ, Braveman PA, Ackerson L, et al. A randomized comparison of home visits and hospital-based group follow-up visits after early postpartum discharge. Pediatrics. Sep. 2001;108(3):719-27. No outcome of interest. [pmid: 11533342].
Fallon AB, Hegney D, O'Brien M, et al. An evaluation of a telephone-based postnatal support intervention for infant feeding in a regional Australian city. Birth. Dec. 2005;32(4):291-8. Historical control. [pmid: 16336370].
Finigan V. Providing breastfeeding support to ethnically diverse groups of mothers. Professional Nurse. May. 2003;18(9):524-8. No control group.
Gagnon AJ, Dougherty G, Jimenez V, et al. Randomized trial of postpartum care after hospital discharge. Pediatrics. Jun. 2002;109(6):1074-80. In Britton 2006 systematic review. [pmid: 12042545].
Gilchrist D, Woods B, Binns CW, et al. Breastfeeding and health promotion: the experience of Aboriginal and non-Aboriginal mothers. Health Promotion J Au s. Dec. 2004;15(3):226-30. Observational study.
Gonzalez KA, Meinzen-Derr J, Burke BL, et al. Evaluation of a lactation support service in a children's hospital neonatal intensive care unit. J oum Lact. Aug. 2003;19(3):286-92. Neonatal ICU.
Gorbe E, Kohalmi B, Gaal G, et al. The relationship between pacifier use, bottle feeding and breast feeding. J Maternal-Fetal & Neonatal Med. Aug. 2002;12(2):127-31. Observational study.
Graffy J, Taylor J, Willliams A, et al. Randomised controlled trial of support from volunteer counsellors for mothers considering breast feeding.[see comment]. BMJ. Jan 3. 2004;328(7430):26. In Britton 2006 systematic review. [pmid: 14703543].
Graffy J, Taylor J. What information, advice, and support do women want with breastfeeding?. Birth. Sep. 2005;32(3):179-86. In Britton 2006 systematic review. [pmid: 16128971].
Heath AL, Tuttle CR, Simons MS, et al. A longitudinal study of breastfeeding and weaning practices during the first year of life in Dunedin, New Zealand. J Am Diet Assoc. Jul. 2002;102(7):937-43. Observational study. [pmid: 12146555].
Hedges S, Simmes D, Martinez A, et al. A home visitation program welcomes home first-time moms and their infants. Home Healthcare Nurse. May. 2005;23(5):286-9. No concurrent control. [pmid: 15891472].
Hoddinot P, Chalmers M, Pill R. One-to-one or group-based peer support for breastfeeding? Women's perceptions of a breastfeeding peer coaching intervention. Birth. Jun. 2006;33(2):139-46. Survey. [pmid: 16732780].
Hoddinott P, Lee AJ, Pill R. Effectiveness of a breastfeeding peer coaching intervention in rural Scotland. Birth. Mar. 2006;33(1):27-36. Before-after study. [pmid: 16499529].
Hofvander Y. Breastfeeding and the Baby Friendly Hospitals Initiative (BFHI): organization, response and outcome in Sweden and other countries. Acta Paediatrica. Aug. 2005;94(8):1012-6. Review. [pmid: 16188842].
Hogan M, Westcott C, Griffiths M. Randomized, controlled trial of division of tongue-tie in infants with feeding problems.[see comment]. J Paediatr & Child Health. May. 2005;41(56):246-50. No comparative Bf outcome. [pmid: 15953322].
Inch S, Law S, Wallace L. Hands off! The Breastfeeding Best Start Project (2). Practising Midwife. Dec. 2003;6(11):24-5. No outcome of interest. [pmid: 14694878].
Ingram J, Johnson D. A feasibility study of an intervention to enhance family support for breast feeding in a deprived area in Bristol, UK. Midwifery. Dec. 2004;20(4):367-79. No interventions. [pmid: 15571885].
Ingram J, Johnson D, Greenwood R. Breastfeeding in Bristol: teaching good positioning, and support from fathers and families. Midwifery. Jun. 2002;18(2):87-101. Historical control. [pmid: 12139907].
Kanng N, Song Y, Hyun TH, et al. Evaluation of the breastfeeding intervention program in a Korean community health center. Int J Nursing Studies. May. 2005;42(4):409-13. Historical control.
Kersting M, Dulon M. Assessment of breast-feeding promotion in hospitals and follow-up survey of mother-infant pairs in Germany: the SuSe Study. Public Health Nutr. Aug. 2002;5(4):547-52. No interventions. [pmid: 12186663].
Khoury AJ, Mitra AK, Hinton A, et al. An innovative video succeeds in addressing barriers to breastfeeding among low-income women. J Hum Lact. May. 2002;18(2):125-31. No outcome of interest. [pmid: 12033073].
Khoury AJ, Hinton A, Mitra AK, et al. Improving breastfeeding knowledge, attitudes, and practices of WIC clinic staff. Public Health Reports. Sep. 2002;117(5):453-62. No outcome of interest. [pmid: 12500962].
Kluka, S. M. A randomized controlled trial to test the effect of an antenatal educational intervention on breastfeeding duration among primiparous women. Thesis/Dissertation
Kools EJ, Thijs C, Kester AD, et al. A breast-feeding promotion and suppot program a randomized trial in The Netherlands. Preventive Medi. Jan. 2005;40(1):60-70. In Britton 2006 systematic review.
Kovach AC. A 5-year follow-up study of hospital breastfeeding policies in the Philadelphia area: a comparison with the ten stepss. J Hum Lact. May. 2002;18(2):144-54. Cross-sectional survey. [pmid: 12033076].
Kramer MS, Guo T, Platt RW, et al. Breastfeeding and infant growth: biology or bias?[see comment]. Pediatrics. Aug. 2002;110(2:Pt 1):t-7. Observational study. [pmid: 12093941].
Mamiro PR, Van CJ, Roberfroid D, et al. Nutritional problems of infants in Kilosa district, rural Tanzania, and appropriate interventions. Mededelingen (Rijksuniversiteit Te Gent. 2001;Fakulteit(4):291-4. No interventions.
Martens PJ. Increasing breastfeeding initiation and duration at a community level: an evaluation of Sagkeeng First Nation's community health nurse and peer counselor programs. J Hum Lact. Aug. 2002;18(3):236-46. Descriptive, retrospective study. [pmid: 12192958].
Memmott MM, Bonuck KA. Mother's reactions to a skills-based breastfeeding promotion intervention. Maternal & Child Nutri. Jan. 2006;2(1):40-50. Duplicate publication (MILK study).
Merewood A, Chamberlain LB, Cook JT, et al. The effect of peer counselors on breastfeeding rates in the neonatal intensive care unit: results of a randomized controlled trial. Arch Pediatr & Adolesc Med. Jul. 2006;160(7):681-5. Premature infants only. [pmid: 16818832].
Merten S, Dratva J, ckermann-Liebrich U. Do baby-friendly hospitals influence breastfeeding duration on a national level?. Pediatrics. Nov. 2005;116(5):e702-e708. Retrospective study. [pmid: 16263985].
Mikiel-Kostyra K, Mazur J, Boltruszko I. Effect of early skin-to-skin contact after delivery on duration of breastfeeding: a prospective cohort study.[see comment]. Acta Paediatrica. 2002;91(12):1301-6. Observational study. [pmid: 12578285].
Philipp BL, Merewood A, Miller LW, et al. Baby-friendly hospital initiative improves breastfeeding initiation rates in a US hospital setting.[see comment]. Pediatrics. Sep. 2001;108(3):677-81. Retrospective study. [pmid: 11533335].
Philipp BL, Malone KL, Cimo S, et al. Sustained breastfeeding rates at eding rates at a US baby-friendly hospital. Pediatrics. Sep. 2003;112(3:Pt 1):t-6. Retrospective study.
Pugh LC, Milligan RA, Frick KD, et al. Breastfeeding duration, costs, and benefits of a support program for low-income breastfeeding women. Birth. Jun. 2002;29(2):95-100. In Britton 2006 systematic review. [pmid: 12000411].
Quinlivan JA, Box H, Evans SF. Postnatal home visits in teenage mothers: a randomised controlled trial. Lancet. Mar 15. 2003;361(9361):893-900. In Britton 2006 systematic review. [pmid: 12648967].
Radford A. Baby friendly education standards. Aiming to improve breastfeeding training. Practising Midwife. Jan. 2003;6(1):32-3. Communication. [pmid: 12599969].
Rowe-Murray HJ, Fisher JR. Baby friendly hospital practices: cesarean section is a persistent barrier to early initiation of breastfeeding. Birth. Jun. 2002;29(2):124-31. No interventions. [pmid: 12000413].
Schlickau, J. M. Prenatal breastfeeding education: an intervention for pregnant immigrant Hispanic women. Thesis/Dissertation
Shaw R, Wallace L, Cook M, et al. Perceptions of the Breastfeeding Best Start psing Midwife. Jan. 2004;7(1):20-4. No outcome of interest.
Sheehan D, Watt S, Krueger P, et al. The impact of a new universal postpartum program on breastfeeding outcomes. J Hum Lact. Nov. 2006;22(4):398-408. No concurrent control. [pmid: 17062785].
Siddell E, Marinelli K, Froman RD, et al. Evaluation of an educational intervention on breastfeeding for NICU nurses. J Hum Lact. Aug. 2003;19(3):293-302. No interventions. [pmid: 12931781].
Simmer K. Telephone-based peer support increased the duration of breastfeeding in primiparous mothers. ACP Journal Club. Sep–Oct. 2002;137(2):68. Commentary. [pmid: 12207446].
Sisk JE, Greer AL, Wojtowycz M, et al. Implementing evidence-based practice: evaluation of an opinion leader strategy to improve breast-feeding rates. Am J Obstetr & Gynecol. Feb. 2004;190(2):413-21. Actual BF rate not measured.
Stevens B, Guerriere D, McKeever P, et al. Economics of home vs. hospital breastfeeding support for newborns. J Adv Nursing. Jan. 2006;53(2):233-43. No relevant outcome.
Stremler J, Lovera D. Insight from a breastfeeding peer suppoding peer support pilot program for husbands and fathers of Texas WIC pacipants. J of Hum Lact. Nov. 2004;20(4):417-22. Historical control. [pmid: 15479662].
Taveras EM, Capra AM, Braveman PA, et al. Clinician support and psychosocial risk factors associated with breastinuation. Pediatrics. Jul. 2003;112(1:Pt 1):t-15. Retrospective study. [pmid: 12837861].
Vittoz JP, Labarere J, Castell M, et al. Effect of a training program for maternity ward professionals on duration of breastfeeding. Birth. Dec. 2004;31(4):302-7. Historical control. [pmid: 15566343].
Vogel AM, Hutchison BL, Mitchell EA. The impact of pacifier use on breastfeeding: a prospective cohort study. J Paediatr & Child Health. Feb. 2001;37(1):58-63. Observational study. [pmid: 11168872].
Wagner CL, Hulsey TC, Southgate WM, et al. Breastfeeding rates at an urban medical university after initiation of an educational program. Southern Med J. Aug. 2002;95(8):909-13. Historical control. [pmid: 12190230].
Walker ML. Telephone based peer support increased duration of breast feeding in primiparous mothers. Evidence-Based Nursing. Jul. 2002;5(3):75. Abstract. [pmid: 12123259].
Wallace H, Clarke S. Tongue tie division in infants with breast feeding difficulties. Int J Pediatr Otorhinolaryngol. Jul. 2006;70(7):1257-61. No interventions. [pmid: 16527363].
Watt RG, McGlone P, Russell JJ, et al. The process of establishing, implementing and maintaining a social support infant feeding programme. Public Health Nutrition. Sep. 2006;9(6):714-21. No interventions. [pmid: 16925876].
Winterburn S, Jiwa M, Thompson J. Maternal grandmothers and support for breastfeeding. J Comm Nursing 2006 Sep;2003 Dec; 17(12):4. In Britton 2006 systematic review
Woods A, Dykes F, Bramwell R. An intervention study using a breastfeeding positioning and attachment tool. Clinical Effectiveness in Nursing. Sep–Dec. 2002;6(34):134-42. Historical control.
Zuckerman B, Parker S, Kaplan-Sanoff M, et al. Healthy Steps: a case study of innovation in pediatric practice. Pediatrics. Sep. 2004;114(3):820-6. Observational study. [pmid: 15342859].