# Appendix C. Evidence Tables

Author | Anderson | Year | 2005 | UI | 16143742

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | N | January 2003 to July 2004 | Government

Type (Description) of BF promotion intervention | Peer counseling: 3 prenatal home visits, 9 postpartum home visits, and daily in-hospital visits during postpartum hospitalization, from the assigned peer counselor. This is in addition to the routine breastfeeding support and education (BFHI).
Who implemented the BF promotion intervention? | Peer counselor, who had successfully breastfed a child for no less than 6 months and who had the motivation to help other mothers breastfeed their infants. An international board-certified lactation consultant trained these women over 2 weeks using the 40-hour WHO/US Children's Fund Breastfeeding Counseling Training Course and the Hispanic Health Council Breastfeeding Training Manual, while the exclusive breastfeeding component was handled by the study field coordinator.
Comparator (Description) | BFHI: breastfeeding warm line (telephone support), conventional breastfeeding education prenatal, hands-on breastfeeding assistance and education from the maternity ward nursing staff.
Inclusion Criteria | 18 years or older, GA of 32 weeks or younger, healthy and absence of any medical condition that is likely to impair successful breastfeeding. Considering breastfeeding, planning deliver at the hospital, willing to stay in the study area for >3 months after delivery, living in a household. Born at term (≥36 weeks gestation), with normal birth weight (≥ 2.5 kg), with no neonatal medical complications requiring treatment in the neonatal intensive care unit, and with Apgar scores at 1 and 5 minutes ≥6 | Exclusion Criteria | None
Other Population Description | 72% Hispanic; 18% Black 90% WIC participants | Setting | Hospital and home
Comments | Predominantly Latina low-income community

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 90 | | 92
Mean Age
Age Range | metric | <20 | 9.5 | | 16.7
Age Range | metric | 20–30 | 68.3 | | 66.7
>30 | 22.2 | 16.7
Gestational Age: | | | >=36 | | >=36
Range | metric:
Baseline SES Measure: | | >High School education | 31.8 | | 31.9
Range | metric:
Duration of BF promotion | | | 3 prenatal home visits, 9 postpartum home visits, and daily in-hospital visits during postpartum hospitalization. The mean total duration of the prenatal home visits and in-hospital visits was 2.6 hours and 2.2 hours, respectively.
Duration of Followup (after the intervention stopped) | | | 3 months postpartum | | 3 months postpartum
Comments: | Baseline characteristics were reported for 135 women who completed the 3-month follow-up. 162 women were enrolled. The authors stated that there were no significant differences in the baseline characteristics between the completers and the dropouts.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Assigned by the study field coordinator | N | Y | ND | 15 | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Coverage by the peer counselors ranged from 56 (88.9%) of 63 for the prenatal home visits to 40 (63.5%) of 63 at week 6 postpartum. About 3% of mothers in the control group reported having received breastfeeding counseling from the existing hospital's peer counseling service during postpartum hospitalization at the maternity ward. 4 mothers in the intervention group declined to see the study peer counselor.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RR (compared control to intervention group) | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | At hospital discharge | 63 | | 57 (91%) | 72 | | 61 (76%)
Exclusive BF initiation rate | At hospital discharge | 63 | | 39 (59%) | 72 | | 32 (44%)
BF at 3 mo rate | Self-report, phone follow-up | 63 | | 31 (49.2%) | 72 | | 26 (36.1%)
Exclusive BF at 3 mo rate | No other food besides breastmilk (since birth recall) | 63 | | 13 (20.6%) | 72 | | 1 (1.4%)
Infant health outcomes | Experiencing 1 or more diarrhea episodes during the study | 63 | | 11 (17.5% | 72 | | 27 (37.5%) | RR of diarrhea, compared control to intervention group = 2.15 | 1.16–3.97
maternal health outcomes | Menses return at 3 months postpartum | 63 | | 30 (47.6%) | 72 | | 48 (66.7%) | RR of menses return, compared control to intervention group = 1.4 | 1.03–1.90

APPLICABILITY | | | QUALITY
Predominantly Hispanic, low income | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may restrict the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Unclear whether the outcome assessors were blinded; inappropriate allocation concealment;15% lost to follow-up

Author | Bonuck | Year | 2005; 2006 (2 publications) | UI | 16322166; 6953019

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | Y - 2 community health center attached to one hospital | Aug 2000 – Nov 2002 | Government agencies

Type (Description) of BF promotion intervention | Individualized, prenatal: first meeting for feeding intentions and benefits of breastfeeding; second meeting on how to initiate breastfeeding (latch-on, positioning, importance of early initiation, demand feeding) Individualized postnatal: Weekly near term telephone calls, Education and support for breastfeeding; provide nursing bras, manual or minielectric pump
Who implemented the BF promotion intervention? | Lactation consultants (LC)
Comparator (Description) | No contact with LCs, received standard of care; had prenatal care class that did not address infant feeding in detail
Inclusion Criteria | English or Spanish speaking; twin or singleton pregnancy; gestation before 24 weeks; intent to keep infant; with regular follow up until 12 mo | Exclusion Criteria | Any chronic medical illnesses or chronic therapy (HIV, gestational diabetes etc..)
Other Population Description | Study conducted in Bronx NY, the county with highest poverty rate and lowest median household income | Setting | 2 community health center
Comments | Moms into Learning about Kids (MILK) study;

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 188 | | 194
Mean Age | | | 25.7 | | 24.84
Age Range | | | ±6.38 | | ±5.86
Gestational Age: | | | nd | | nd
Range | metric:
Baseline SES Measure: | | High school education % | 58.5 | | 63.5
Medicaid % | 53.7 | | 58.2
Range | metric:
Duration of BF promotion | | | 2 prenatal meetings, a postpartum hospital visit, and/or home visits and telephone calls. Prenatal and home visits averaged 60 min; hospital visits averaged 90 min.
Duration of Followup (after the intervention stopped) | | | 52 wks | | 52 wks
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Blocked and stratified according to center | Yes (sealed envelope) | Y | No (unblended) | 11% (for certain outcomes); 20.5% missing BF data | Y | Y | Y
List the variables that were adjusted for: | | | Prenatal breastfeeding intentions; maternal age; ethnicity; Medicaid status; and previous breastfeeding
Were statistical analyses appropriate? ^iv^ (Y/N) | | | yes
Comments | Used backward stepwise regression model and logistic regression model

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | Any BF at 2 wk | 145 | | 90% | 159 | | 65% | | | nd
BF at 3 mo rate | Low versus high breastfeeding at 13 wk | Total (both groups) = 304 | | | | | | | | | 1.0 (intervention) Control 1.90 | 1.13–3.20 | <.05
BF rate up to week 20 | Any breastfeeding Up to week 20 | 145 | | 53.0% | 159 | | 39.3% | | | <0.028
BF rate at 1 yr | At the end of 12 mo | 145 | | 18% | 159 | | 15% | | | NS
Low versus high breastfeeding at 52 wk | Total (both groups) = 304 | | | | | | | | | Control = 2.50 | 1.48–4.21 | <.05
Exclusive breast feeding rates | At 13 wks | 145 | | 9% | 159 | | 11% | | | NS
At 26 wk | 145 | | 5% | 159 | | 8% | | | NS
Infant health outcomes** (visits with illness) | Illness | 163 | | | 175 | | | β -0.07 | -0.28 to 0.14 | NS | β -0.06 | -0.29 to 0.17 | NS
Infant health outcomes** (visits with illness) | Breast-feeding sensitive illness | 163 | | | 175 | | | β 0.01 | -0.20 to 0.23 | NS | β 0.25 | -0.10 to 0.59 | NS
Infant health outcomes** (visits with illness) | GI illness | 163 | | | 175 | | | β 0.03 | -0.10 to 0.16 | NS | β 0.03 | -0.09 to 0.53 | NS
Infant health outcomes** (visits with illness) | RS tract illness | 163 | | | 175 | | | β -0.02 | -0.21 to 0.18 | NS | β -0.02 | -0.21 to 0.18 | NS
Otitis Media | | | | | β 0.02 | -0.11 to 0.15 | NS | β 0.20 | 0.0 to 0.39 | <.05

APPLICABILITY | | | QUALITY
Hispanic, African-American, low income, 39% foreign born | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possiblesignificant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US up, dropouts) primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
20.5% missing BF data

Bosnjak, 2004 UI 15636080

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Intervention | Control Intervention
Mean age (range): nd Mean GA (range): nd Enrolled/Evaluate: 7,414 / 7,208 @ 1mo; 7,139 @ 3 mo; 6,880 @ 6 mo Location: Croatia Sites: Multi Funding: nd | Observational, retro- and prospective study of one county in Croatia; comparing no-intervention, BFHI, and BFHI+postnatal support. Data on BF for no intervention and BFHI were collected retrospectively from medical records; BF data for BFHI+postnatal support were obtained from child health card at discharge, 1, 3, 6, 9, and 12 mo. | ND | BFHI (1994-98) or BFHI + postnatal support (1999-2000) Not full BFHI because mothers received Happy Baby discharge packs. | No intervention (1990-93)

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | | Bias/limitations Comments
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | Mean prevalence of BF | | | | | | A: strong, B: moderate, C: weak | A | B | C
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | | 1 mo | 3 mo | 6 mo* | 9 mo* | 11/12 mo* | Selection | | x
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | No intervention (1990-93) | 1917/2818 (68%) | 856/2818 (30%) | 323/2818 (11%) | 173/2818 (6%) | 63/2818 (2%) | Study design | | | x
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | BFHI (1994-98) | 1967/2257 (87%) | 1212/2257 (54%) | 640/2257 (28%) | 332/2257 (15%) | 41/1179 (3%) | Confounder | | | x
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | BFHI + postnatal support (1999-2000) | 1854/2133 (87%) | 1369/2064 (66%) | 891/1805 (49%) | 423/1214 (35%) | 210/921 (23%) | Blinding | | | x
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | * chi2, P < 0.05 | | | | | | Data collection | | | x
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | | | | | | | Withdraw and dropout | | | x
Ever BF: at least one meal of BF per day | Descriptive and chi2; no data on confounders | | | | | | | Analyses | | | x
| | | | | | Large lost-to follow-up; no adjustment for confounders

Applicability

Study characteristics that one is likely to encounter in US primary care | Given hospital discharge pack “Happy Baby”, use of visiting nurses
Study characteristics that may limit the applicability to a US primary care population | A highly selected sample from Croatia
Overall assessment of applicability to US primary care (wide or narrow) | Narrow

Author | Boulvain | Year | 2004 | UI | 15270928

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Switzerland | nd | 1998-2000 | Government

Type (Description) of BF promotion intervention | Short hospital stay (24–48h, 2 d extra for c-section) with home care provided by midwife (number of visits determined by needs of the family)
Who implemented the BF promotion intervention? | nd
Comparator (Description) | Normal hospital stay (3 to 4 d after vaginal delivery, 2 d extra for c-section)
Inclusion Criteria | >37 wk gestation, low risk for complications or c-section | Exclusion Criteria | Strong preference for short or long hospital stay
Other Population Description | | Setting | Home or hospital
Comments | Some in the hospital-based group received midwife visits as well (1.7 visits as opposed to 4.8 visits in the short hospital stay group)

CHARACTERISTICS | | | Home-based | | Hospital-based
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 228 | | 231
Mean Age | | | 29 | | 29
Age Range | metric
Gestational Age: | | | >37 | | >37
Range | metric:
Baseline education ≤ 13 yr: | | | 115 | | 113
Range | metric:
Duration of BF promotion | | | On average 4.8 visits
Duration of Followup (after the intervention stopped) | | | 6 mo
Comments: | 1964/2324 eligible (85%) refused enrollment

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random blocks | Y | Y | N | 0.5% | N | Y | Y
List the variables that were adjusted for:
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Home based vs. hospital based: nulliparity (60% vs 57%); smoking (25% vs 17%)

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | Home-based | | | Hospital-based | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | | 227 | | 224 (99%) | 229 | | 223 (97%) | 1.01* | 0.99–1.04
BF rate at 1 mo | | 224 | | 202 (90%) | 223 | | 194 (87%) | 1.04* | 0.97–1.11
BF rate at 6 mo | | 220 | | 78 (35%) | 215 | | 78 (36%) | 0.98 | 0.76–1.3
EPDS > 12 at 28 days | Edinburgh Postpartum Depression Scale | 228 | | 16 (7.4%) | 231 | | 21 (9.4%) | 0.79 | 0.42–1.5

* recalculated to reflect the ratio of BF initiation rate in home-based/hospital-based

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
BF duration | days | home | | | 127 | | | 0.42
hospital | | | 121
QOL - physical health | SF-12 (No data on when the maternal quality of life data was collected) | home | 228 | | 46 | 7.9 | | NS
hospital | 231 | | 45 | 8.6
QOL - mental health | SF-12 (No data on when the maternal quality of life data was collected) | home | 228 | | 47 | 10 | | NS
hospital | 231 | | 48 | 9.6
Results Comments | Early discharge after c-section was not acceptable to many women, therefore, low compliance in this group (8%). Some women in home-based early discharge did not receive any midwife visits; while some hospital-based subjects did receive midwife visits. Even though ITT was done, unclear what proportion actually completed the protocol.

APPLICABILITY | | QUALITY
Middle income, low risk (for cesarean section and postnatal complications) mothers | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
85% of eligible subjects refused enrollment; 97% BF initiation rate in the control group. | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Incomplete and inconsistent data reporting. No data on when the maternal quality of life data was collected. Maternal morbidity outcomes were only assessed once, so whether the groups were similar in terms of the morbidity profile was unclear.

Broadfoot, 2005 UI 2009109512 (Cinahl)

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Interventions | Control Interventions
Mean age (range): nd Mean GA (range): nd Enrolled/Evaluate: 464,246 / 445,623 Location: Scotland Sites: Multi Funding: SPorting Aiding Medical Research for KidS | Observational study, prospective cohort with historical control analyzed with respect to progress towards BFHI status Postal questionnaires between 3/2000 and 5/2001 to midwife at 33 maternity units with ≥ 50 births per year; collected BFHI status in the questionnaire; 1995-2000 data provided by BFHI; feeding status at 6–7 d collected by Guthrie dataset (check box for breast, bottle, or other feeding) | Excluded if born outside Scotland, <4 d or >30 d | WHO/UNICEF UK Baby Friendly Hospital Initiative standard award | No Baby Friendly accreditation

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | A: strong, B: moderate, C: weak | A | B | C
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Selection | | x
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Study design | | | x
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Confounder | | x
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Blinding
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Data collection | | | x
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Withdraw and dropout | x
nd | Adjustment for deprivation category, maternal age, number of births at hospital, and year of birth | 445,623 records included (96%) adjOR of BF at 7 d was 1.28 (95%CI 1.24 to 1.31) if born in hospitals with a UK BFHI standard award | Analyses | | x
No details concerning BF

Applicability

Study characteristics that one is likely to encounter in US primary care
Study characteristics that may limit the applicability to a US primary care population | BF status collected on Guthrie Inborn Errors Screening card at 7 d of age
Overall assessment of applicability to US primary care (wide or narrow) | Narrow

Author | Carfoot | Year | 2004 | UI | 15177863

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | United Kingdom | N | ND | North West regional Health Authority

Type (Description) of BF promotion intervention | Skin-to-skin contact: after birth, newborn is weighed and then immediately placed between mother's breasts naked in a prone position until mother chooses to stop the contact or until newborn appears to be ready for feeding
Who implemented the BF promotion intervention? | Midwife
Comparator (Description) | Routine care: after birth, newborn is dried and clothed, and then given to either parent. Parent-newborn contact could be broken off due to baby weight measurement, dressing for the baby, or mother's perineum suturing
Inclusion Criteria | Healthy Pregnant Plan to breast-feed Plan to deliver at Warrington Hospital Fetus is at least 36 weeks old and is healthy Provide informed consent | Exclusion Criteria | Requested to have or not to have skin-to-skin contact Had previous multiple pregnancy Expecting multiple pregnancy
Other Population Description | | Setting | Hospital
Comments | This is a pilot study to see if a bigger study is feasible. The later trial is published: UI 15740818. 67% consent rate. Enrollment dependent on the availability of the clinical coordinator.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 14 | | 14
Mean Age | | | 31 | | 30
Age Range | metric
Gestational Age: | | | ≥ 36 weeks | | ≥ 36 weeks
Range | metric:
Baseline SES Measure: | | | ND | | ND
Range | metric:
Duration of BF promotion | | | ND
Duration of Followup (after the intervention stopped) | | | 4 months | | 4 months
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Computer-generated randomization list, sequence of envelops | N | N | N | 7.1% | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | N/A
Comments | This is a pilot study, so no hypothesis testing.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RD | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
Success of first BF | Breastfeeding Assessment Tool (BAT) score 8 or higher | 13 | | 13 (100%) | 13 | | 8 (62%) | | | Not done
BF at 4 months | Exclusive BF | 13 | | 5 (36%) | 13 | | 4 (32%) | | | Not done
BF at 4 months | Partial BF | 13 | | 2 (14%) | 13 | | 1 (8%) | | | Not done

Results Comments | Clinical coordinator observed first feed.

APPLICABILITY | | QUALITY
| Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Small pilot study | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Outcome assessors were not blinded. Exclusivity of breastfeeding was not clearly defined. A pilot study, so no hypothesis testing. Small sample size.

Author | Carfoot | Year | 2005 | UI | 15740818

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | United Kingdom | N | April 28 to September 1 2002 | North West regional Health Authority

Type (Description) of BF promotion intervention | Skin-to-skin contact: after birth, newborn is weighed and then immediately placed between mother's breasts naked in a prone position until mother chooses to stop the contact or until newborn appears to be ready for feeding
Who implemented the BF promotion intervention? | Midwife
Comparator (Description) | Routine care: after birth, newborn is dried and clothed, and then given to either parent. Parent-newborn contact could be broken off due to baby weight measurement, dressing for the baby, or mother's perineum suturing
Inclusion Criteria | Healthy Pregnant Plan to breast-feed Plan to deliver at Warrington Hospital Fetus is at least 36 weeks old and is healthy Provide informed consent | Exclusion Criteria | Requested to have or not to have skin-to-skin contact Had previous multiple pregnancy Expecting multiple pregnancy
Other Population Description | | Setting | Hospital
Comments | 75% response rate

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 100 | | 101
Mean Age | | | ND | | ND
Age Range | metric
Gestational Age: | | | ≥ 36 weeks | | ≥ 36 weeks
Range | metric:
Baseline SES Measure: | | | ND | | ND
Range | metric:
Duration of BF promotion | | | 45 minutes
Duration of Followup (after the intervention stopped) | | | 4 months | | 4 months
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Computer-generated randomization list, sequence of envelops | N | Y | N | 3.4% | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RD | 95% CI | P between
Individual | Group | Individual | Group
BF before discharge | Subsequent BF while at hospital | 96 | | 91 | 101 | | 97 | -1.2% | -8.1% 5.3%
BF at 4 months | Exclusive or partial BF | 97 | | 42 | 100 | | 40 | 3.3% | -10.3% 16.7% | 0.64
Success of first BF | Breastfeeding Assessment Tool (BAT) score 8 or higher | 98 | | 89 | 99 | | 82 | 8% | -1.6% 17.6% | 0.10

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
Mean time to first breastfeeding | minutes | BF promotion | 98 | | 46 | 22.2 | 1.3 (-5.1, 7.6) | 0.7
Control | 99 | | 45 | 22.8
Median duration of first feeding | minutes | BF promotion | 97 | | 40 | 95%CI: 32, 40 | 0 (-5, 5) | 0.99
Control | 97 | | 35 | 95%CI: 33–40

Results Comments | Research assistant revealed the treatment group and also observed the first breastfeeding (?).

APPLICABILITY | | QUALITY
| Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
First feed observed by research assistant, sparse demographic data | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Outcome assessors were not blinded. Exclusivity of breastfeeding was not clearly defined.

Cattaneo, 2001 UI 11739226

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Interventions | Control Interventions
Mean age (range): Group 1 = 29.0 to 29.3; Group 2 = 30.0 to 31.0 Mean GA (range): nd Enrolled/Evaluate: Group 1 = 1531/1219 @ 6 mo; Group 2 = 1055/962 @ 6 mo Location: Italy Sites: Multi Funding: Government | Non-randomized before-after study; training hospital practice to use baby-friendly steps; Training: UNICEF 18 h course with 2 h of WHO counseling course; Phase 1: baseline assessment of number of steps compliant with BFHI requirement, then training; Phase 2: after training; Phase 3: final assessment Mothers interviewed at discharge, phone interviews at 3 and 6 mo 2 groups of hospitals; initiated training at different times. | 8 hospitals agreed to participate. Infants with birth weight under 2000 g or a severe disease that required admission to the neonatal ward were excluded. | UNICEF BFHI training | Before BFHI training

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | Before training: fulfilled 1–3 BFHI steps After training: fulfilled 6–10 BFHI steps Group 1 (crude rates): Baseline exclusive BF at discharge: 212/518 (41%) Final exclusive BF at discharge: 393/510 (77%) Baseline exclusive BF at 3 mo: 101/506 (20%) Final exclusive BF at 3 mo: 129/510 (25%) Baseline exclusive BF at 6 mo: 3/485 (0.6%) Final exclusive BF at 6 mo: 3/366 (0.8%) Group 2 (crude rates): Baseline exclusive BF at discharge: 105/464 (23%) Final exclusive BF at discharge: 194/271 (72%) Baseline exclusive BF at 3 mo: 69/471 (15%) Final exclusive BF at 3 mo: 127/280 (45%) Baseline exclusive BF at 6 mo: 4/454 (0.9%) Final exclusive BF at 6 mo: 30/233 (13%) Standardized rates do not differ significantly. In both group, differences before and after training in exclusive BF at discharge, full BF at 3 mo, ever BF at 6 mo were significant (P<0.05) | A: strong, B: moderate, C: weak | A | B | C
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | | Selection | | | x
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | | Study design | | | x
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | | Confounder | | x
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | | Blinding | | | x
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | | Data collection | | x
Exclusive BF (no other foods or fluid) Predominant BF (non-nutritive fluids allowed) Full (exclusive and Predominant BF) Complementary BF data collected by 24h recall. | BF rates adjusted with direct standardization by parity, type of delivery, and birth weight; logistic regression | | Withdraw and dropout | | | x
Analyses | | | x

Applicability

Study characteristics that one is likely to encounter in US primary care | Low number of BFHI-certified hospitals in Italy, comparable to US (1% vs. 1.3%, see www.babyfriendly.org), low infant mortality rate; large and small hospitals
Study characteristics that may limit the applicability to a US primary care population
Overall assessment of applicability to US primary care (wide or narrow) | Wide

Author | Chertok | Year | 2006; 2004 (2 publications) | UI | 16603986; 15214252

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Prospective Cohort with comparative group | Israel | N | 2000-2002 | Not stated

Type (Description) of BF promotion intervention | Post-caesarean breastfeeding support, guidance, and education. Education covers benefits of early breastfeeding, benefits of exclusive breastfeeding, guidance on post-caesarean positioning, latching, and other infant feeding information. For those with elective cesarean delivery, breastfeeding education is provided prior to delivery. Newborn is placed with mother within first 4 hours of birth (immediately in recovery room if mother desires and not sedated) so that maternal-infant contact and/or breastfeeding is possible.
Who implemented the BF promotion intervention? | Certified lactation consultant and/or trained medical or nursing students
Comparator (Description) | Standard postpartum care, no mother-newborn interaction for at least first 2 hours after birth
Inclusion Criteria | Muslim or Jewish Healthy mothers Post-cesarean delivery without complication Full term, singleton infants Speaks either Arabic, English, Hebrew, or Russian | Exclusion Criteria | Premature or postmature infants Infants with “apparent problems” Mothers with compromised maternal health or complicated delivery
Other Population Description | | Setting | Hospital
Comments | Recruited by interviewers on days when interviewers are present, so only 53.8% of eligible mothers were invited to participate Overall refusal rate=8.6% Control group subjects were recruited from December 2000 through July 2001, while intervention group subjects were recruited from December 2001 to July 2002.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 306 | | 264
Mean Age | | | See comments below | | See comments below
Age Range | metric
Gestational Age: | | | Full term - not specified | | Full term - not specified
Range | metric:
Baseline SES Measure: | | Maternal education level (years) | See comments below | | See comments below
Range | metric:
Duration of BF promotion | | | SSC, one-time education and breastfeeding support at hospital
Duration of Followup (after the intervention stopped) | | | 16 weeks postpartum | | 16 weeks postpartum
Comments: | | Age and education level are presented after stratified by ethnicity (Jewish or Muslim), not by treatment. The mean maternal age for all women was 30.5 years old, and mean education was 10.7 years.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
N | N | Y | N | 19% | Y | Y | ND
List the variables that were adjusted for: | | | Previous BF experience, postpartum smoking, BF education
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Authors did not state how they choose what variables to adjust, but reported what variables are “significant” in the model. The adjusted results were not reported.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | Not defined | 306 | | 101+201=302 (98.69%) | 264 | | 88+154=242 (91.67%)
BF initiation rate | Initiate BF within 0–4 hours after birth | 306 | | 29+87=116 (37.91%) | 264 | | 11+49=60 (22.72%)
Overall BF at 10 weeks | Any amount of breastfeeding | 306 | | 132+94=226 (73.86%) | 264 | | 91+90=181 (68.56%)
Exclusive BF at 10 weeks | No nutritional food supplements or liquids except vitamin and mineral supplements within the past 24 hours | 306 | | 95+28=123 (40.20%) | 264 | | 51+19=70 (26.52%)
Overall BF at 16 weeks | Any amount of breastfeeding | 306 | | 113+87=200 (65.36%) | 264 | | 67+90=157 (59.47%)
Exclusive BF at 16 weeks | No nutritional food supplements or liquids except vitamin and mineral supplements within the past 24 hours | 306 | | 65+16=81 (26.47%) | 264 | | 29+4=33 (12.5%)

Results Comments | Data are calculated by compiling data from different tables. Results of BF initiation rates and BF within 0–4 hours are from Chertok 2006, while results of BF rates at 10 weeks and 16 weeks are from Chertok 2004.

APPLICABILITY | | QUALITY
Healthy Jewish and Muslim women post-cesarean section | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Enrolled only 49% of eligible population, conducted in one hospital only in Israel | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
19% lost to follow-up. Control group was recruited during different time periods. Adjusted results were not reported Recruitment of subjects depended on availability of interviewer.

Evidence table for Systematic Reviews of Breastfeeding Promotion

Author, Year | Title | Britton, 2006 | Support for breastfeeding mother
Literature search (Dates) | | Medline (1966 to November 2005); Other databases searched? (yes); unpublished data used? (no)
Countries where primary studies conducted | | No country restriction, including developed and developing countries Included studies are from 14 countries: Canada, USA, UK, Brazil, Bangladesh, Australia, India, Nigeria, Italy, Iran, the Netherlands, Belarus, Mexico, and Sweden
Study eligibility / inclusion criteria | | - Randomized or quasi-randomized controlled trials, with or without blinding, and with a minimum of 75% follow up; - Pregnant or postpartum women intending to breastfeed, or women breastfeeding their babies; - Postnatal and/or antenatal Intervention/support that was offered by either professional or volunteer to an individual or individuals which is supplementary to standard care with the purpose of facilitating continued breastfeeding; - Excluded studies with intervention that occur only in antenatal period; - Excluded studies with intervention that is only educational.
Study design [No. Of studies] | | 34 trials were included
No. of subjects | | 29,385 mother-baby pairs
Study population (definition in included studies) | | Pregnant women who plan to breastfeed, or currently lactating women
Intervention/Exposure (definition in included studies) | | Additional breastfeeding support by health professionals (medical personnel, nursing staff, allied health professionals), and/or lay people
Comparator (definition in included studies) | | Routine maternity care at the time of studies
Outcomes (definition in included studies) | | - Rate of partial or exclusive breastfeeding of various time points (2 weeks to 1 year after birth).; - Duration of breastfeeding; - Neonatal and infant morbidity; - Maternal satisfaction with care or feeding method
Heterogeneity assessments | | There was heterogeneity in all groups of studies categorized by type of interventions as indicated by I^2^ test
Quality assessments | | 15 of the 34 included studies used adequate allocation concealment Drop out rate Statistical analysis used Blinding Intention to treat analysis
Publication bias assessments | | No data
Statistical Analysis or meta-analytic methods | | Random-effects models
Results | | - Any breastfeeding support intervention increases breastfeeding duration up to 6 months (RR of stopping BF: 0.91, CI: 0.86–0.96).; - Any breastfeeding support intervention increases breastfeeding rate among areas with intermediate breastfeeding initiation rate (RR of stopping BF: 0.92, CI: 0.85–0.98), but not in areas with low or high breastfeeding initiation rates.; - Professional breastfeeding support increases any breastfeeding at only 4 months (RR of stopping BF: 0.78, CI: 0.67–0.91), and increases exclusive breastfeeding up to 3 months.; - Lay support is effective in increasing any breastfeeding (RR of stopping BF: 0.86, CI: 0.76–0.98) and exclusive breastfeeding (RR of stopping BF: 0.72, CI: 0.57–0.90) before last study assessment; - Combined professional and lay support reduces breastfeeding termination (RR of stopping BF: 0.84, CI: 0.77–0.92).; - Face-to-face support is effective in decreasing breastfeeding termination (RR of stopping BF: 0.85, CI: 0.79–0.92) but telephone support is not (RR of stopping BF: 0.92, CI: 0.78–1.08).; - Postnatal support is effective in decreasing breastfeeding termination (RR of stopping BF: 0.89, CI: 0.84–0.96) but antenatal support is not (RR of stopping BF: 0.92, CI: 0.83–1.02).; - In three studies, recurrence of infant diarrhea is decreased (RR: 0.70, CI: 0.54–0.9). (comparing what groups?)
Author's interpretations of the results | | All forms of support increases breastfeeding duration Lay support and combined lay/professional support increase exclusive breastfeeding duration. Recommend face-to-face support rather than telephone intervention
Quality | | Fair

Author | Coutinho | Year | 2005 | UI | 16182897

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Brazil | Y | 2001 | Government

Type (Description) of BF promotion intervention | BFHI plus 10 postnatal home visits by trained hospital staff
Who implemented the BF promotion intervention? | Community health agents or recruited staff
Comparator (Description) | BFHI only
Inclusion Criteria | Singletons, ≥ 2500g | Exclusion Criteria | Serious disease in infants or mothers, planning to leave the area within 6 mo
Other Population Description | Recruited from urban areas and 3 neighboring small towns | Setting | Hospital and home
Comments | Usual stay is 24 h after vaginal delivery, and 48 h after c-section; strong traditions of giving water and tea from birth, and early introductions of milk and pacifiers

CHARACTERISTICS | | | BFHI + home visits | | BFHI (in hospital only)
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 175 | | 175
Maternal age <20 y | | | 52% | | 64%
Age Range | metric
Gestational Age: | | | ≥ 2500g | | ≥ 2500g
Range | metric:
Baseline SES Measure: | | <0.5 minimum wage | 107 | | 102
Mother literate (yes) | | | 132 | | 131
Duration of BF promotion | | | 10 visits
Duration of Followup (after the intervention stopped) | | | 6 mo | | 6 mo
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random number table | Y | Y | Y | 6% | N | Y | Y
List the variables that were adjusted for:
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BFHI + home | | | BFHI (in hospital only) | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
Exclusive BF initiation rate | Assessed in the maternity ward (day 1) | 161 | | 70% | 169 | | 70%
Exclusive BF at 1 mo | estimated from Fig 2 | | | 15% | | | 65%
Exclusive BF at 3 mo | estimated from Fig 2 | | | 45% | | | 10%
Exclusive BF at 6 mo | estimated from Fig 2 | | | 25% | | | 4%
Aggregate exclusive BF rate days 10–180 | | | | 45% | | | 13% | | | <0.0001
Aggregate Ever BF rate days 10–180 | | | | 78% | | | 62% | | | <0.0001

Results Comments | Proportion of SES “better-off” mothers (P=0.02) and better-educated mothers (P=0.01) who breastfed exclusively at 1 mo were higher than “poorer” or less educated mothers.

APPLICABILITY | | QUALITY
Usual postpartum stay is 24 h after vaginal delivery | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Widespread poverty, high infant mortality rate, maternal illiteracy rate of ~30%, strong traditions of giving water and tea from birth | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)

Dulon, 2003 UI 12856972 (see also Kersting 2002, UI 12186663 for supplementary information)

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Interventions | Control Interventions
Mean age (range): 91% ≥ 25 Mean GA (range): ≥ 37 Eligible/Enrolled mothers: 3,294/1,487 Location: Germany Sites: Multi Funding: government | Observational cohort, a prospective cohort; random sample of 360 hospitals in Germany were drawn; hospitals were rated by breastfeeding promotion index (low (≤ 5) or high (>5) using 10 indicators similar to Baby Friendly 10 steps); mother's full breastfeeding status was assessed at 4 months (only breast milk, no other foods except for vitamins or meds) | BW≥ 2,500 g; GA ≥ 37 wk; no admittance to NICU; familiar with German language; has phone at home | Hospitals with high breastfeeding promotion index (>5) | Hospitals with low breastfeeding promotion index (≤5)

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | Age, education, area of upbringing (East vs. West Germany), breastfeeding promotion index, hospital size, geographic location of hospital (East vs. West Germany); Bivariate associations between categorical variables analyzed using contingency tables, chi2 statistics and phi coefficient. Unit of analysis: mother | 17/360 hospitals and 1,487/3,294 mothers in final analysis; Median breastfeeding promotion index was 5 index points (fulfilled 5 of 10 steps); 12 hospitals (6.8%) >7 index points; 1 hospital (0.6%) achieved the maximum of 10 index points Adj OR of increased risk of short-term BF in a hospital with low BF promotion index: 1.24 (95%CI 0.99 – 1.55); Associations of short-term BF with maternal age < 25, low education level (discrepancy between table 4 and text), and upbringing in East Germany, were stronger. | A: strong, B: moderate, C: weak | A | B | C
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Selection | | x
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Study design | | | x
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Confounder | | x
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Blinding | | x
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Data collection | | x
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Withdraw and dropout | | x
Short-term: < 4 mo; long-term: ≥ 4 mo full BF Full BF: exclusive and predominant BF (non-nutritive fluids allowed) Women were prospectivel6y followed for the breastfeeding duration. | | | Analyses | | x
Low enrollment rate; self-selection bias

Applicability

Study characteristics that one is likely to encounter in US primary care | Large hospitals, low number of BFHI-certified hospitals in Germany, comparable to US (1.8% vs. 1.3%, see www.babyfriendly.org)
Study characteristics that may limit the applicability to a US primary care population | Typical postpartum stay of 5 days, BF interaction with specific geographic location (former East vs. West Germany)
Overall assessment of applicability to US primary care (wide or narrow) | Narrow

Author | Ekstrom | Year | 2006 | UI | 16732777

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Quasi-RCT (centers or caregivers were randomized) | Sweden | Y | September 1999 to March 2000 (the intervention training) April 2000 and June 2002 (the follow-up period) | University

Type (Description) of BF promotion intervention | Process-oriented program on breastfeeding counseling for health professionals and continuity in family classes through childbirth: lectures on breastfeeding management and promotion, counseling skills and personal breastfeeding experience
Who implemented the BF promotion intervention? | health professionals
Comparator (Description) | Standard routine care: family classes through the point of birth
Inclusion Criteria | Swedish-speaking mothers who gave birth to singleton, healthy, full-term babies delivered spontaneously, by vacuum extraction, or by cesarean section. | Exclusion Criteria | Mothers who had given birth to babies with life-threatening diseases or malformations
Other Population Description | | Setting | Hospital
Comments

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 206 | | 172
Mean Age | | | 26.6 | | 27.0
Age Range | metric
Gestational Age: | | weeks | 40.4 | | 40.4
Range | metric:
Baseline SES Measure: | | High school University | 37% 36% | | 41% 36%
Range | metric:
Duration of BF promotion | | | “7 sessions”
Duration of Followup (after the intervention stopped) | | | 9 months postpartum | | 9 months postpartum
Comments: | There were 2 control groups in the study. Data collection for control group A started before the intervention; that for control group B was collected simultaneously with data collection for the intervention group. Therefore, only control group B was reviewed for the purpose of our report.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Randomized pairwise. Centers were matched in pairs that were similar in size and had similar figures of breastfeeding duration. | Y | N | ND | ND (can be as high as 33%) | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Incomplete reporting for breastfeeding outcomes. Based on the sample sizes reported for other outcomes, only 145 and 132 subjects provided 3-month follow-up data in the intervention and control group, respectively. Only 131 (64%) and 125 (73%) subjects provided 9-month follow-up data in intervention and control group, respectively.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | Not described | 206 | | 100% | 172 | | 97% | | | NS

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
Exclusive BF duration | breastmilk only but including some babies received supplementary feeding with formula during the first week of life (months) | BF promotion | ND | | 3.9 | 2.2 | | NS
Control | ND | | 3.5 | 2.0
Any BF duration | Exclusive and partial breastfeeding | BF promotion | ND | | 7.5 | 4.7 | | NS
Control | ND | | 7.0 | 4.5
Results Comments | The intervention group mothers perceived that they received better breastfeeding information and better breastfeeding support than control group mothers. There was no significant difference in perceived emotional support at the antenatal clinic between intervention group mothers and control group mothers.

APPLICABILITY | | | QUALITY
Large municipalities, majority had either high school or college education | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Very high background breastfeeding initiation rate (~100%) | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Incomplete reporting; differential rates of lost to followup between the intervention and the control groups; high lost to followup rates; unclear if the outcome assessors were blinded.

Author | Finch | Year | 2002 | UI | 12146564

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | N | ND | ND

Type (Description) of BF promotion intervention | Breastfeeding education with incentives for exclusive breastfeeding. Incentive marketing in the form of a truth or myth activity; followed by instruction and discussion accompanied by handouts.
Who implemented the BF promotion intervention? | A trained counselor
Comparator (Description) | Usual prenatal education regarding general benefits and barriers to breastfeeding.
Inclusion Criteria | Urban WIC participants who were English speaking, pregnant, and HIV negative | Exclusion Criteria | ND
Other Population Description | Poverty, primary African-American and Hispanic; 25% were 18 years old or younger | Setting | WIC
Comments | Women who exclusively breastfed, or did not receive formula, were eligible to receive a food package valued at more than $50 per month. Mothers who exclusively breastfed for >2 months were also eligible to receive a $25 mall gift certificate. These incentives were provided to both groups.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 30 | | 30
Mean Age | | | ~20 | | ~22
Age Range | metric | | | | 16.7
Gestational Age: | | | ND | | ND
Range | metric:
Baseline SES Measure: | | NY WIC program serving a mostly minority population with the highest poverty level in the city | 100% | | 100%
Range | metric:
Duration of BF promotion | | | ND
Duration of Followup (after the intervention stopped) | | | 2 months postpartum
Comments: | 11 participants were lost from the intervention group: 3 due to miscarriage or infant death, 1 due to relocating, the remaining lost due to not attending the intervention.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
N | N | N | ND | 37% | N | Y (presumed) | ND
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Yes
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF education | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate (determined at WIC infant enrollment by interview plus medical documentation) | Exclusive | 19 | | 9 (47%) | 29 | | 5 (17%) | | | 0.025
BF initiation rate (determined at WIC infant enrollment by interview plus medical documentation) | Partial | 19 | | 6 (32%) | 29 | | 15 (52%) | | | NS
None | 4 (21%) | 9 (31%) | NS

RESULTS: Continuous measures

Outcome | Definition (units) | Group | | No. Analyzed | | Final | Range | Net difference | P between
Individual | Group
BF duration | Median breastfeeding duration at 2 months (weeks) | BF education | Exclusive | 9 | | 12 | 7–12 | N/A | 0.017
BF duration | Median breastfeeding duration at 2 months (weeks) | BF education | Partial | 6 | | 5 | 1–12 | N/A | 0.088
BF duration | Median breastfeeding duration at 2 months (weeks)
BF duration | Median breastfeeding duration at 2 months (weeks) | All subjects | 19 | | 12 | 0–12 | NS
BF duration | Median breastfeeding duration at 2 months (weeks)
Control | Exclusive | 5 | | 12 | 5–12
Control | Partial | 15 | | 12 | 1–12
All subjects | 29 | | 5 | 0–12
Results Comments | Most women in the study indicated they valued at least one of the incentives. In the intervention group, 16 of 18 (88%) listed at least one of the suggested incentives as having value compared with 23 of 29 (79%) control group participants. There were no significant differences in the types of incentives chosen.

APPLICABILITY | | | QUALITY
Primarily African-American and Hispanic; 25% were 18 years old or younger, urban WIC program participants | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
37% in intervention did not complete study | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Incomplete data reporting. High dropout rate in intervention group (37%). Subjects were followed for 2 months postpartum. However, median BF duration is more than 2 months. It is unclear how investigators obtained those data.

Author | Forster | Year | 2004 | UI | 15330879

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Australia | N | May 1999 to August 2001 | Government and organization

Type (Description) of BF promotion intervention | Intervention 1 (Practical Skills): Single session of 1.5 hours that focused on practical breastfeeding skills, such as the technique of attachment of the baby to the breast (“latching-on”). Partners were not included. Intervention 2 (Attitudes): Two 1-hour sessions that focused on changing attitudes to breastfeeding. Partners were encouraged to join.
Who implemented the BF promotion intervention? | Midwives and a community educator with specific training in childbirth education. Lactation consultant qualifications were not required.
Comparator (Description) | Control group: Women could access the standard care, which included formal breastfeeding education sessions; breastfeeding information as a component of standard childbirth education courses; lactation consultant support as necessary (inpatient and outpatient); peer support by means of community breastfeeding groups; optional attendance at a breastfeeding information evening; any videos or education on breastfeeding presented in the postnatal ward; 24-hour telephone counseling support; and a postnatal home visit by a domiciliary midwife.
Inclusion Criteria | Public patients; having a first child; between 16 and 24 weeks pregnant at time of recruitment; and able to speak, read, and write in English. | Exclusion Criteria | Physical problems that prevented breastfeeding, and choosing birth center or private obstetric care.
Other Population Description | | Setting | Hospital
Comments | Recruitment was in the ultrasound department when women attended for their mid-trimester scan, at 18 to 20 weeks.

CHARACTERISTICS | | | Breastfeeding promotion | | | Control
CHARACTERISTICS | | | Individual level | | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
Practical Skills | Attitudes
No. Enrolled | | | 327 | 327 | | 327
Mean Age | | | 28.0 | 28.2 | | 28.7
Age Range | metric
Gestational Age: | | | ND | ND | | | ND
Range | metric:
Baseline SES Measure: | | Completed secondary school | 71.1% | 75.5% | | 78.7%
Pension/benefit primary family income | 14.6% | 16.0% | | 7.2%
Duration of BF promotion | | | Single session of 1.5 hours | Two 1-hour sessions
Duration of Followup (after the intervention stopped) | | | 6 months after birth | | | 6 months after birth
Comments: | Of the women allocated to the intervention 1 (Practical Skill), 3 were not eligible to attend the class (1 miscarriage, 1 termination, and 1 birth before the class date). Attendance was 213/324 (66%). Of the women allocated to the intervention 2 (Attitudes), 4 were not eligible to attend (births took place before class dates). Attendance was 190/323 (59%) at the first class and 132/323 (41%) at the second.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
A computerized system of biased urn randomization | N | N | ND | 7% | Y | Y | Y
List the variables that were adjusted for: | | | Income, smoking before pregnancy, and education
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Yes
Comments | Attendance of the interventions was low.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF education | | | | Control (Standard Care) | | | Unadjusted / Adjusted (if noted)
Outcome | Definition | No. Analyzed | | No. Events | | No. Analyzed | | No. Events | OR | 95% CI | P between
Practical Skills | Attitudes | Practical Skills | Attitudes | Individual | Group
BF initiation rate *Exclude baby not feeding yet | Interview 2–4 days after birth | 306 | 308 | | | 310
BF initiation rate *Exclude baby not feeding yet | - Breastmilk only (breastmilk is the only nutritional intake, either breast or expressed) | | | 238 (77.8%) | 239 (77.6%) | | | 242 (78.1%) | P/S*=0.98 A/S*=0.97 | 0.67–1.44 0.66–1.42 | NS NS
BF initiation rate *Exclude baby not feeding yet | - Any breastmilk (mixed breastmilk and formula used) | | | 296 (96.7%) | 291 (94.5) | | | 297 (95.8%) | P/S*=1.30 A/S*=0.75 | 0.56–3.00 0.36–1.57 | NS NS
- Baby not feeding yet | | | 2 | 4 | 3
BF > 3 mo rate
BF > 6 mo rate | 6-month interview | 297 | 293 | | | 299
BF > 6 mo rate | - Exclusive breastfeeding up to 6 mo | | | 26 (8.8%) | 25 (8.5%) | | | 22 (7.4%) | P/S*=1.20 A/S*=1.17 | 0.67–2.18 0.66–2.13 | NS NS
BF > 6 mo rate
- Breastmilk only (breastmilk is the only nutritional intake, either breast or expressed, although this may include solids, water or juice) | | | 107 (36.0%) | 99 (33.7%) | | | 105 (35.1%) | Adj P/S* =1.19 Adj A/S* =1.06 | 0.83–1.70 0.74–1.52 | NS NS
- Any breastmilk (mixed breastmilk and formula used, and may include solids, water or juice) | | | 162 (54.5%) | 146 (49.8%) | | | 162 (54.2%) | Adj P/S* =1.26 Adj A/S* =1.03 | 0.88–1.79 0.73–1.46 | NS NS

* P/S compared Practical Skills group with standard care. A/S compared Attitudes group with standard care.

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
BF duration | Mean duration at 26 weeks (weeks) | Practical Skills | 297 | | 19 | 9.3 | +1 | NS
BF duration | Mean duration at 26 weeks (weeks) | Attitudes | 293 | | 17 | 10.2 | -1 | NS
Control (standard care) | 299 | | 18 | 9.7

Results Comments | The breastfeeding initiation rate was high in the study population (78% In the standard care group). Breastfeeding duration comparisons using survival analysis confirmed that there were no significant differences among the groups (log-rank test, p=0.28)

APPLICABILITY | | | QUALITY
Low income, culturally diverse, subjects recruited from public health system | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
95% breastfeeding initiation rate; BFHI accredited hospital | | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Attendance of the interventions was low: <66%

Gau, 2004 [UI#15050853]

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Intervention | Control Intervention
Mean age (range): 31 (16–45) Mean GA (range): 38.8 (28–34) Enrolled/Evaluate: 4,614 / nd Location: Taiwan Sites: Multi Funding: government | Non-randomized pre-post design at 7 hospitals | Any breastfeeding women | Lactation intervention program (Baby Friendly 10 steps) in hospital (> 9 in BF promotion index (maximum of 10 points in the index)) | 7 hospitals comparable in the number of births and hospital accreditation, and volume. 2 hospitals withdrew from the study because their caseload in the maternity department decreased gradually to zero.

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | | | | | Bias/limitations Comments
Breastfeeding initiation rate and duration: including exclusive breastfeeding and mixed breastfeeding. Exclusive BF: only breast milk from the mother or a wet nurse, or expressed breast milk, and no other liquids or solids with the exception of drops or syrups consisting of vitamins, mineral supplements, or medicine. Mixed BF: breast milk ingested along with formula milk (regardless of the number of feedings). | Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | | | 2000 | | 2001 | | 2002 | | A: strong, B: moderate, C: weak | A | B | C
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | | | BFHI | Control | BFHI | Control | BFHI | Control | Selection | | | x
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | | n | 1339 | 380 | 1144 | 568 | 869 | 313 | Study design | | | x
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | Exclusive BF rates in hospital | % | 34 | 22 | 46 | 23 | 50 | 23 | Confounder | | | x
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | Exclusive BF 2 mo rate | % | 6 | 5 | 8 | 3 | 12 | 0 | Blinding
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | Exclusive breastfeeding rate of the BFHI group was higher than that of the control group in hospital, at 2 weeks, 1 and 2 months postpartum (p<0.001). Mixed breastfeeding rate was higher in the control group than that of the experimental group in hospital, at 2 weeks, 1 and 2 months postpartum (p<0.001). However, the overall breastfeeding rate was lower in the Control group. BF rates increased year by year (P<0.001) from 2000 to 2002. | | | | | | | | Data collection | | x
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | | | | | | | | | Withdraw and dropout | | | x
| Repeated measure ANOVA, ANCOVA and Pearson correlation coefficients | | | | | | | | | Analyses | | | x

Applicability

Study characteristics that one is likely to encounter in US primary care | High education, full-time career mothers, maternity leave ~7 wk, active promotion of formula
Study characteristics that may limit the applicability to a US primary care population
Overall assessment of applicability to US primary care (wide or narrow) | Wide

Author | Henderson | Year | 2001 | UI | 11903211

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Australia | N | June to September 1999 | ND

Type (Description) of BF promotion intervention | Postpartum positioning and attachment education: One-to one standardized education session lasting 30 minutes. Main focus of the intervention was the technique of self-positioning and self-attachment by the woman and the cues she could use to determine that her technique was correct.
Who implemented the BF promotion intervention? | The principle investigator (a doctoral student in the School of Nursing and Midwifery)
Comparator (Description) | Usual postpartum breastfeeding care
Inclusion Criteria | First-time, English-speaking mothers who planned to breastfeed and had a singleton, term infant with an Apgar score of 7 more at 5 minutes | Exclusion Criteria | ND
Other Population Description | Usual postpartum breastfeeding care | Setting | Hospital
Comments | Both groups received the usual breastfeeding care provided by the hospital midwives. 184 eligible women approached, 160 consented and were randomized.

CHARACTERISTICS | | | Breastfeeding education | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 80 | | 80
Mean Age | | | 27.6 | | 27.2
Age Range | metric | SD | 5.6 | | 5.7
Gestational Age: | | | term | | term
Range | metric:
Baseline SES Measure: | | College/University Education | 47% | | 52%
Range | metric:
Duration of BF promotion | | | One-to one standardized education session lasting 30 minutes
Duration of Followup (after the intervention stopped) | | | 6 months postpartum
Comments: | High education level

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Computer-generated balanced blocks of 20 in individually sealed opaque envelopes | Y | N | N | 6.25 | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | The principle investigator conducted the intervention and was aware of group allocation. She also conducted the pain assessment in hospital.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RR | 95% CI | P between
Individual | Group | Individual | Group
BF at 6 weeks | Self-report | 79 | | 60 (76%) | 79 | | 65 (82%) | 0.92 | 0.79–1.08 | NS
BF at 3 mo | Self-report | 78 | | 56 (72%) | 76 | | 57 (75%) | 0.96 | 0.79–1.16 | NS
BF at 6 mo | Self-report | 75 | | 42 (56%) | 75 | | 48 (64%) | 0.88 | 0.67–1.14 | NS
Nipple Pain | In Hospital; - Day 1 | 79 | | 4 (5%) | 80 | | 7 (8%) | | | NS
Nipple Pain | - Day 2 | 78 | | 31 (39%) | 79 | | 49 (62%) | | | 0.004
Nipple Pain
Nipple Pain | - Day 3 | 76 | | 39 (51%) | 74 | | 50 (68%) | | | 0.04
Nipple Pain
Self-reported; - 6 wk | 79 | | 21 (30%) | 79 | | 19 (25%) | | | NS
- 3 mo | 78 | | 14 (18%) | 76 | | 12 (16%) | | | NS
- 6 mo | 75 | | 9 (12%) | 75 | | 13 (17%) | | | NS
Nipple Trauma (such as redness, peeling, blistering, bruising, bleeding, cracking, and scabbing) | Self-reported; - 6 wk | 79 | | 14 (17%) | 79 | | 16 (20%) | | | NS
Nipple Trauma (such as redness, peeling, blistering, bruising, bleeding, cracking, and scabbing) | - 3 mo | 78 | | 11 (14%) | 76 | | 10 (13%) | | | NS
- 6 mo | 75 | | 8 (11%) | 75 | | 11 (15%) | | | NS

Results Comments | Higher incidence of nipple trauma was observed in both groups in the first few days in hospital (data not reported).

APPLICABILITY | | | QUALITY
Postpartum stay 2 to 3 d, >95% completed secondary education | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Background breastfeeding initiation rates higher; midwives provide in-home followup to women who gave birth in the public health system; midwives provide postpartum care | | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Researcher aware of group allocation and also assessed one of the outcomes.

Author | Howard | Year | 2003 | UI | 12612229

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | N | 1997-1998 | Government

Type (Description) of BF promotion intervention | Delayed pacifier use (>4 wk) (RCT)
Who implemented the BF promotion intervention? | Research nurse
Comparator (Description) | Pacifier use (days 2–5)
Inclusion Criteria | Intend to BF ≥ 4 wk; undecided about pacifier use, healthy infant with GA ≥ 36 wk | Exclusion Criteria
Other Population Description | | Setting
Comments | Supplemental feeding (non-randomized, but assignment to cup vs bottle was randomized) was also studied, data not summarized here

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 346 | | 354
Mean Age | | | 29 | | 29
Age Range | metric
Gestational Age: | | | ≥ 36 | | ≥ 36
Range | metric:
Education | | | 14.4 yr | | 14.4
Range | metric:
Duration of BF promotion | | | Instruction while in hospital
Duration of Followup (after the intervention stopped) | | | 52 wk
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Opaque envelope, blocks of 20 | y | y | y | 2% | y | y | y
List the variables that were adjusted for: | | | Predictors (Maternal race, previous births, maternal education...and others) with P ≤ 0.10 were retained plus intervention variables (cup vs bottle supplement, early vs delayed pacifier)
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Unclear which predictors were retained in the final adjusted model

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | 95% CI | Adj HR of stop BF | 95% CI | P between
Individual | Group
Exclusive BF | No liquid or solid food besides breast milk (day) | Early pacifier | 354 | | 21 | 17–27 | 1.09 | 0.94–1.27 | NS
Delayed pacifier | 346 | | 28 | 25–30
Full BF | Infrequent use of other liquids (day) | Early pacifier | 354 | | 52 | 42–60 | 1.04 | 0.89–1.21 | NS
Delayed pacifier | 346 | | 49 | 42–63
Ever BF duration | day | Early pacifier | 354 | | 140 | 120–157 | 1.22 | 1.03–1.44 | 0.02
Delayed pacifier | 346 | | 163 | 140–180

APPLICABILITY | | | QUALITY
Primarily white, well-educated, married, 77% employed, wished to use or were undecided about pacifiers | | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)

Johnston, 2006 (6 mo data) UI 16894077; Johnston, 2004 (3 mo data) UI 15110063

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Interventions | Control Interventions
Maternal age: 32.5 (HS), 30.9 (UC) Mean GA (range): nd Mean BW (range): nd % Male: 52% (HS); 56% (UC) Enrolled/Evaluate: 439/343 Location: US Sites: Multi Funding: Kaiser Foundation | Non-randomized comparative: usual care (UC) vs. Healthy Steps (HS), postnatal intervention, with or without PrePare (prenatal intervention); this was determined by randomization Followup until 30 months by phone Population from 5* outpatient clinics in a large HMO, subjects generally were well-educated, middle-income parents. 2 clinics were assigned UC; 3 clinics were assigned HS. Enrollment between 7/1998 and 9/2000 *discrepancy between 2004 and 2006 papers, former reported 4 clinics, latter reported 5 clinics | <22 wk GA at enrollment, <45 yr, English speaking | Healthy Steps (HS), postnatal intervention, with or without PrePare (prenatal intervention) | Usual care

Outcome Definition | Statistical analyses and confounders adjusted | Results | | | | Bias/limitations Comments
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF | Baseline significant difference between maternal education (higher education 93% (HS) vs. 85% (UC)) and age (32.5 (HS) vs 30.9 (UC)). For 6 mo: Maternal education, family income, status as a first-time parent For 3 mo: maternal age, education, family income, paternal education, number of years in health plan, maternal race, child's actual age in weeks0 | 91 in usual care (UC); 232 in HS (HS) | | | | A: strong, B: moderate, C: weak | A | B | C
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF | | | HS (unadjusted) | UC (unadjusted) | Adjusted estimates (95%CI) | Selection | | x
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF | | BF initiation | 97% | 91% | RR 1.06 (1.00 to 1.11) | Study design | | | x
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF | | BF at 3 mo | 91% | 76% | RR 1.14 (1.09 to 1.20) | Confounder | | x
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF | | Duration > 6 mo | 82% | 64% | RR 1.18 (1.11 to 1.26) P<0.05 | Blinding | | | x
BF initiation; any BF at 3 mo; any BF > 6 mo; total duration of BF
Total duration | 13.4 mo | 11.2 mo | Adjusted β 1.30 (0.18 to 2.43) | Data collection | | x
No difference was found between the HS group without PrePare vs. HS with PrePare group (RCT part of the study). Nonrespondents at 30 mo had less education and lower family incomes compared with respondents. At 30 mo, 24% dropout in UC, 21% dropout in HS. Mothers in intervention reported less mental health symptoms (14.2% vs. 17.5%, adj RR 0.61; 95%CI 0.49, 0.76), less depression (adj β: -0.59; 95%CI -0.98, -0.19), lower proportion with CES-D score > cutoff (6.6% vs. 12.5%; adj RR 0.42; 95%CI 0.25, 0.71) Infants at 24 mo, language development did not differ between groups (combining ≥2 words, sometimes/often vs no; adj RR 1.02; 95%CI 0.94, 1.12). | | | | Withdraw and dropout | | | x
| | | | Analyses | | x
| | | | Intervention integrity | | x
Unclear how the clinics got the initial assignments (HS vs. UC).

APPLICABILITY | | | QUALITY
Large health maintenance organization, all subjects have prenatal care, well-educated, middle income | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Unclear how group assignments were made

Author | Kramer | Year | 2001 | UI | 11242425

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Cluster-RCT (subjects clustered within centers/areas were randomized) | Belarus | Y | 1996-1998 | Government, UNICEF, WHO

Type (Description) of BF promotion intervention | Modeled on BFHI; chief obstetrician and chief pediatrician received the BFHI 18h course; full implementation required 12 to 16 mo
Who implemented the BF promotion intervention? | Chief obstetrician and chief pediatrician started the intervention
Comparator (Description) | Standard care
Inclusion Criteria | Intention to BF; healthy infant ≥ 37 wk, ≥ 2,500g, Apgar ≥ 5 | Exclusion Criteria
Other Population Description | | Setting
Comments

CHARACTERISTICS | | | Breastfeeding promotion | | | Control
Individual level | | Group level (if cluster or quasi-RCT) | Individual level | | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 8,865 | | 16 | 8,181 | | 15
Mean Age | | | 14% 81% 4.2% | <20 20–34 >=35 | | 13.5% 82.3% 4.5% | <20 20–34 >=35
Age Range | metric
% Male
Gestational Age: | | | 39.4 | | | 39.3
Range | metric:
Baseline SES Measure:
Range | metric:
Duration of BF promotion
Duration of Followup (after the intervention stopped) | | | 8,547 (12 mo) | | | 7,895 (12 mo)
Comments: | Original 34 sites; 2 refused to participate after randomization; 1 site excluded (falsified data)

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random number table | N | Y | N | 3% | Y | Y | Y
List the variables that were adjusted for: | | | Birth weight, maternal age, history of BF previous infant ≥ 3 mo, number of children in household, maternal smoking, family atopic history
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Yes. Stratification, multivariate modeling of group- and individual-level covariates
Comments | 20 charts were audited from each site: GI, respiratory tract infection, data on BF at 3 mo

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
Any BF at 3 mo | | 8547 | | 72.7% | 7895 | | 60% | | | | 0.52 | 0.40–0.69
Any BF at 6 mo | | | | 49.8% | | | 36.1% | | | | 0.52 | 0.39–0.71
Exclusive BF at 3 mo | | | | 43.3% | | | 6.4% | | | P<0.001*
Exclusive BF at 6 mo | | | | 7.9% | | | 0.6% | | | P=0.01*
Infant health outcomes | ≥1 GI infection | | | 9.1% | | | 13.2% | | | | 0.60 | 0.40–0.91
| ≥2 respiratory infection | | | 39.2% | | | 39.4% | | | | 0.87 | 0.59–1.28
| Atopic dermatitis | | | 3.3% | | | 6.3% | | | | 0.54 | 0.31–0.95

Results Comments | Weight in intervention group exceeded that of control through first 3 mo, then declined somewhat, and then the difference disappeared by 12 months (see UI 12165588) *Unadjusted results because the GLIMMIX modes did not converge and could lead to unreliable estimates of adjusted ORs. Used unpaired t tests for estimates.

APPLICABILITY | | | QUALITY
Sanitary water supply, wide-availability of basic health services | | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Prolonged postpartum stay, prolonged maternity leave, no day care, and expensive formulas | | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)

Author | Kramer | Year | 2001 | UI | 11466098

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Canada | N | 1998-1999 | Government

Type (Description) of BF promotion intervention | Counseling intervention to discourage pacifier use.
Who implemented the BF promotion intervention? | Trained nurse
Comparator (Description) | Control intervention including pacifier to sooth the infant
Inclusion Criteria | Mom intend to BF ≥ 3 mo; ≥ 37wk; ≥ 2,500g | Exclusion Criteria
Other Population Description | | Setting | In hospital and by phone
Comments | Both groups received usual counseling, including positioning, the importance of frequent feeding and feeding on demand, the avoidance of formula and other liquids, the management of sore nipples and breast engorgement, and provided the telephone numbers of persons and agencies whom the mother could call for answers to questions, help with difficulties, and general support

CHARACTERISTICS | | | Discourage Pacifier use | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 140 | | 141
Mean Age | | | 31.6 (SD4.5) | | 31.5 (SD3.2)
Age Range | metric
Gestational Age: | | | ≥ 37 wk | | ≥ 37 wk
Range | metric:
Baseline SES Measure: | | Education (year) | 16.1 | | 16.0
Range | metric:
Duration of BF promotion | | | 45 min
Duration of Followup (after the intervention stopped) | | | 3 mo
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Computer generated blocks of 4 | Y | N | Y | 8% | Y | Y (small baseline differences in marital status and smoking.) | Y
List the variables that were adjusted for: | | | Marital status, smoking
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | Discourage Pacifier use | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% Cl | P between
Individual | Group | Individual | Group
Avoided pacifier use | | 127 | | 38.6% | 131 | | 16% | 2.4 (RR) | 1.5–3.8
Stopped exclusive BF by 3 mo | | 127 | | 63.8% | 131 | | 66.4% | 1.0 (RR) | 0.8–1.1
Weaning by age 3 mo | | 127 | | 18.9% | 131 | | 18.3% | 1.0 (OR) | 0.6–1.9 | | 1.0 (OR) | 0.5–1.9

Results Comments | Observational analysis: 25% of infants with daily pacifier use vs. 12.9% of infants without daily pacifier use stopped BF by 3 mo. “Pacifier use is a marker of breastfeeding difficulties or reduced motivation to breastfeed, rather than a true cause of early weaning.”

APPLICABILITY | | | QUALITY
Multicultural (67% English speaking), well-educated, working mothers (76%) | | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors,<20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias.Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may restrict the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possiblesignificant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data errors in analysis, definitions not clear, poor follow-up, dropouts)

Author | Labarere | Year | 2003 | UI | 14511968

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | France | N | October to late December 2001 | ND

Type (Description) of BF promotion intervention | One-to-one educational session (during hospital stay): feeding positions, importance of feeding on demand, avoidance of formula and pacifier, management of sore nipple and breast engorgement and opportunities for prolonging lactation after returning to work.
Who implemented the BF promotion intervention? | 3 midwives and 1 female intern of the maternity ward staff
Comparator (Description) | Usual care: usual verbal encouragement to maintain breastfeeding provided by the maternity staff.
Inclusion Criteria | In-hospital breastfeeding mothers, 18 years of age or older, speak French, were employed outside of the home parentally, and were delivered of a healthy singleton of >37 weeks of gestational age and of 2500 g birthweight. One mother per room. | Exclusion Criteria | Transferred to the intensive care unit, or infants died during the stay
Other Population Description | | Setting | Hospital
Comments | In France, the paid maternity leave is 6 weeks before giving birth and 10 weeks after. On the birth of the 3^rd^ child, the paid maternity leave is increased to 8 weeks before and 18 weeks after the birth.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 106 | | 106
Mean Age | | | 30.5 | | 30.9
Age Range | metric | SD | 4.6 | | 4.2
Gestational Age: | | | 39.9 | | 40.1
Range | metric: | SD | 1.2 | | 1.2
Baseline SES Measure: | | Partial/complete university education | 57% | | 60.8%
White collar | 88.2% | | 81.4%
Duration of BF promotion | | | 30 minutes
Duration of Followup (after the intervention stopped) | | | 17 weeks postpartum
Comments: | This is open trial

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Computer-generated random numbers in blocks of eights | Y (sealed opaque envelopes opened after consent) | Y | Y | 9.5% | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RR | 95% CI | P between | OR/RR | 95% Cl | P between
Individual | Group | Individual | Group
Self-reported breastfeeding at 17 weeks | As receipt by the infant of any breast milk within the 24 hours preceding the completion of thequestionnaire | 93 | | 32 (34.4%) | 97 | | 39 (40.2%) | 0.86 | 0.52–1.40
Self-reported exclusive breastfeeding at 17 weeks | Giving maternal milk as the only food source since the birth, with no other liquids (other than vitamins or medications) or food given | 93 | | 13 (14.0%) | 97 | | 14 (14.4%) | 0.97 | 0.42–2.22
Breastfeeding difficulties | | 93 | | 41.(44.1%) | 97 | | 51.(52.6%) | 0.84 | 0.54–1.29

Results Comments

APPLICABILITY | | | QUALITY
Employed mothers, well-educated | | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors,<20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
French law requires employers to allow mothers to breastfeed or express milk at work; subjects selected from one maternity ward in France | | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possiblesignificant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data errors in analysis, definitions not clear, poor follow-up, dropouts)
Unclear if giving a handbook to the 4 professionals was sufficient tostandardize the intervention.

Author | Labarere | Year | 2005 | UI | 15687421

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | France | N | October 1, 2001 to May 31, 2002 | Government and university

Type (Description) of BF promotion intervention | A routine, preventive, outpatient visit in a primary care physician's office within 2 weeks after the birth, in addition to the usual predischarge and postdischarge support.
Who implemented the BF promotion intervention? | Pediatricians or family physicians, who had attended a 5-hour training program delivered in 2 parts in 1 month before the beginning of the study. The training program was intended to improve the physicians' breastfeeding-related knowledge and counseling skills.
Comparator (Description) | Usual postdischarge support: Verbal encouragement to maintain breastfeeding, provided by the maternity ward staff. Peer support group was also provided.
Inclusion Criteria | Mothers who had delivered a healthy singleton infant (GA ≥37 weeks) and were breastfeeding on the day of discharge | Exclusion Criteria | Infants admitted to a neonatal unit or mother was transferred to an intensive care unit, ≤18 years ofage, living outside of the study area and its suburbs, refused or was unable to give consent, unable to speak French, or unlikely to complete follow-up due to psychosocial problems such a s homelessness.
Other Population Description | | Setting | Physician's office
Comments | Consecutive mother-infant pairs were screened and recruited on the day of discharge.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 116 | | 115
Mean Age | | | 29.3 | | 29.7
Age Range | metric | year | >18 | | >18
Gestational Age: | | weeks | 39.7 | | 39.8
Range | metric: | SD | 1.3 | | 1.2
Baseline SES Measure: | | >high school education | 75% | | 73%
White-collar worker | 79.3% | | 75.6%
Duration of BF promotion | | | 1 outpatient visit within 2 weeks after birth
Duration of Followup (after the intervention stopped) | | | 1 month | | 1 month
Comments: | 72 mothers (79.3%) assigned to the intervention group and 8 mothers (7%) assigned to the control group attended the routine, preventive, outpatient visit (the intervention)

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random permuted blocks with a block size of 8 | Y (numbered, sealed, opaque envelopes) | Y | N | 2 | Y | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Age, education more than high school graduate, white-collar worker, smoking history, prenatalclass attendance, primiparity, epidural anesthesia, GA at delivery, infant birth weight, breastfedwithin 1 hr after birth, postpartum length of stay of >4 days, expected breastfeeding duration >4 months
Comments | Dependent variable of the multivariate analysis was exclusive breastfeeding at 4 weeks.All other analyses were univariate.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | HR | 95% CI | P between | OR | 95% Cl | P between
Individual | Group | Individual | Group
Exclusive breastfeeding at 4 weeks | Maternal milk as the only food source, with no other liquids (other than vitamin or medication) or food | 112 | | 94 (83.9)% | 114 | | 82 (71.9)% | 1.17 | 1.01–1.34 | 0.03 | 2.44 | 1.18–5.03
Any breastfeeding at 4 weeks | Based on 24-hr recall | 112 | | 100 (89.3%) | 114 | | 93 (81.6%) | 1.09 | 0.98–1.22 | 0.10
Reporting any breastfeeding difficulties | | 112 | | 62 (55.3%) | 114 | | 83 (72.8%) | 0.76 | 0.62–0.93 | <0.01

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final (Median) | SD/SE | Hazard Ratio (95%CI) | P between
Individual | Group
BF duration | Any breastfeeding (weeks) | BF promotion | 112 | | 18 | | 1.40 (1.03–1.92) | 0.03
Control | 114 | | 13

Results Comments | 8 mothers in control did attend routine preventive visits. 24 mothers in intervention did not attend routine preventive visits.

APPLICABILITY | | | QUALITY
Routine postnatal newborn care delivered by MD during the first 6 mo; majority had >high schooleducation, white-collar worker | | Factors reported in the study that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias.Must be RCT, cluster RCT, or non-randomized, controlled study.
Postpartum stay ~5 d after normal vaginal delivery | | Factors reported in the study that one is unlikely to encounter in US primary care | | C Poor quality: Prospective or retrospective. Cannot exclude possiblesignificant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data errors in analysis, definitions not clear, poor follow-up, dropouts)

Author | Lavender | Year | 2005 | UI | 16045516

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Cluster-RCT (subjects clustered within centers/areas were randomized) | UK | Y | July 1,1998 | Government

Type (Description) of BF promotion intervention | Standard antenatal care plus a breastfeeding educational support session: To assist midwives to revise their knowledge of lactation management and to educate women on basic lactation physiology and effective breastfeeding techniques. One day intervention 9am to 4pm.
Who implemented the BF promotion intervention? | Midwives
Comparator (Description) | Standard antenatal care that included breastfeeding advice from attending midwives and information about hospital parent education classes
Inclusion Criteria | Women who were registered with a practice sited in one of the eight wards randomized. No fetal abnormality was detected at their 20-week ultrasound. Desire to breastfeed. | Exclusion Criteria | Ward with an outlying Underprivileged Area score (UPA)
Other Population Description | >90% White | Setting | Hospital
Comments | Of 1649 eligible women, 337 declined to participant: no difference in the 2 groups.

CHARACTERISTICS | | | Breastfeeding education | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 679 | 4 | 633 | 4
Mean Age | | | 29.6 | | 29.7
Age Range | metric | SD | 5.3 | | 5.4
Gestational Age: | | | ND | | ND
Range | metric:
Baseline SES Measure: | | Deprivation score | 20.8 | | 19.4
Range | metric: | Mean
Duration of BF promotion | | | Single session 1 day
Duration of Followup (after the intervention stopped) | | | 12 months
Comments: | Of the 679 women allocated to the intervention arm, 439 (64.7%) attended the workshop; 5 women in the control arm also attended the workshop but were retained in their allocated group for analysis.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Opaque sealed envelopes | Y | Y | Y (statistician was blinded) | 5 – 7 | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Wards were pair matched base on UPA. Within each pair, one ward was randomly allocated to the intervention group and one to the control group by a midwife, independent of the trial

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF education | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR | 95% CI | P between | OR/RR | 95% Cl | P between
Individual | Group | Individual | Group
BF initiation rate | Breastfeeding rate at discharge | 679 | | 517 | 633 | | 463 | 1.2 | 0.8–1.7 | NS
BF at 4 mo rate | Note: 65 missing data | 646* | | 202 | 600* | | 192 | | | NS
Exclusive BF at 4 mo | Total No. of event = 232 | | | | | | | 1.1 | 0.6–1.8 | NS
BF at 6 mo rate | Note: 73 missing data | 642* | | 140 | 596* | | 138 | | | NS
BF at 12 mo rate | Note: 80 missing data | 639* | | 60 | 593* | | 61 | | | NS

* Estimated from assuming equal number of missing data per group

Results Comments | 42% and 44% women in the control and intervention group achieved their expected duration of breastfeeding, respectively (p=NS) No difference between the 2 groups in the proportion of women who attended routine antenatal classes [136 (51.5%) vs. 147 (51.8%)]

APPLICABILITY | | | QUALITY
Low income, lack of social support, difficulties of feeding in public, inconsistent advice from health professionals | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias.Must be RCT, cluster RCT, or non-randomized, controlled study.
1/3 of the subjects did not get the intended intervention | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possiblesignificant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data errors in analysis, definitions not clear, poor follow-up, dropouts)
Only 64.7% of women in intervention attended the workshop.

Author | McKeever | Year | 2002 | UI | 12431265

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Canada | N | 7/1999 to 12/2000 | Government

Type (Description) of BF promotion intervention | Home visits from lactation nurses (maximum of 3 home visits)
Who implemented the BF promotion intervention? | Lactation nurses
Comparator (Description) | No lactation nurses visits
Inclusion Criteria | BF at discharge, ≥ 21 yr, ≥ 35 wk gestation and others | Exclusion Criteria | Did not speak English, C-section, postpartum complications, infant with hyperbilirubinemia and others
Other Population Description | | Setting | home
Comments | Outcomes assessed at 5 to 12 days postpartum

CHARACTERISTICS (Term Infant) | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 53 | | 48
Mean Age | | | 32 (SD4.2) | | 33 (SD4.4)
Age Range | metric:
Gestational Age: | | | ≥ 37 | | ≥ 37
Range | metric:
Baseline SES Measure: | | | ND
Range | metric:
Duration of BF promotion | | | maximum of 3 home visits
Duration of Followup (after the intervention stopped) | | | Outcomes assessed at 5 to 12 days postpartum
Comments:

CHARACTERISTICS (Near-Term Infants 35–37 wk) | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 19 | | 18
Mean Age | | | 32 (SD2.9) | | 32 (SD4.4)
Age Range | metric
Gestational Age: | | | ≥ 35 | | ≥ 35
Range | metric:
Baseline SES Measure: | | “well-educated” | ND
Range | metric:
Duration of BF promotion
Duration of Followup (after the intervention stopped) | | | Outcomes assessed at 5 to 12 days postpartum
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Central | ND | N | N | 26% (term study); 27% (preterm study) | N | Y | Y
List the variables that were adjusted for:
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% Cl | P between
Individual | Group | Individual | Group
Exclusive BF rate in past 24 h in term infants | BF by breast and excluding supplementation with expressed breast milk or formula | 41 | | 40 (98%) | 34 | | 30 (87%) | | | 0.01
Exclusive BF rate in past 24 h in near-term infants | | 15 | | 12 (83%) | 12 | | 10 (87%) | | | 0.93

Results Comments

APPLICABILITY | | | QUALITY
Metropolitan area, well-educated mothers, postpartum stay ~48h | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Mothers were not isolated (ie, had accessible family and friends to provide help if necessary) | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Short followup, small sample size, large drop out, no adjustment

Author | McLeod | Year | 2004 | UI

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Quasi-RCT (centers or caregivers were randomized) | New Zealand | Y | 1999-2000 | Government

Type (Description) of BF promotion intervention | Breastfeeding group: Midwife trained in BF education (a program of education and support for breastfeeding for women who smoked) provided care (observation of BF, information sheet) Breastfeeding + smoking education: midwives received training to implement both the smoking education and breastfeeding education
Who implemented the BF promotion intervention? | midwives
Comparator (Description) | Usual care or smoking cessation group
Inclusion Criteria | All midwives in selected localities in New Zealand (lower North Island), continue to practice for next 12 mo | Exclusion Criteria
Other Population Description | All women in this study were smokers | Setting | Prenatal and postnatal
Comments

CHARACTERISTICS
Control | BF support | Smoking cessation | combined
No. Enrolled | | | 60 | 60 | 69 | 108
Mean Age | | | 24.9 | 26.1 | 27.3 | 25.1
Maori Ethnicity | | | 42% | 36% | 20% | 27%
Gestational Age:
Range | metric:
Tertiary education | | | 42% | 29% | 43% | 42%
Range | metric:
Duration of BF promotion
Duration of Followup (after the intervention stopped) | | | 4 mo postpartum
Comments: | Clustering was not taken into account in these comparisons.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random number | N | Y | N | 164/275 (60%) | Y | N | Y
List the variables that were adjusted for: | | | unclear
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | Control | | | BF support | | | Smoking cessation | | | Combined
Proportion | | Adj OR (95%CI) | Proportion | | Adj OR (95%CI) | Proportion | | Adj OR (95%CI) | Proportion | | Adj OR (95%CI)
BF initiation rate | At discharge | 25/30 | 83% | | 16/23 | 70% | | 35/42 | 83% | | 46/52 | 89%
BF at 6 wk rate | | 22/31 | 71% | ref | 12/20 | 60% | 0.73 (0.18–2.84) | 23/34 | 68% | 0.74 (0.22–2.52) | 37/48 | 77% | 1.20 (0.36–4.04)
BF at 4 mo rate | | 12/25 | 48% | ref | 7/19 | 37% | 0.81 (0.18–3.58) | 14/28 | 50% | 0.73 (0.22–2.50) | 22/47 | 47% | 0.97(0.25–3.70)

Results Comments | BF outcome collected by postal questionnaire; Women who had decreased or stopped smoking were more likely to BF fully at 6 wk (adj OR for cluster 4.46, 95%CI 1.55–12.85)

APPLICABILITY | | | QUALITY
Smokers | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias.Must be RCT, cluster RCT, or non-randomized, controlled study.
Primary maternity care delivered by midwives alone, less often with a general practitioner or obstetrician; no fee for women attending a midwife or general practitioner; same provider provides ante-, intra- and post-natal care; | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possiblesignificant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data errors in analysis, definitions not clear, poor follow-up, dropouts)
Large drop out; did not take into account clustering in demographic comparisons

Author | Minkovitz | Year | 2001 | Ref ID | | UI | 11296075 | Reviewer | SI

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) And non-randomized comparative | US | Y | 1996-1998 | Commonwealth Fund

Type (Description) of BF promotion intervention | Healthy Steps Program for Young Children: well-child care emphasis on child development, home visits by Healthy Steps Specialist, phone info, written materials, parent groups, and others
Who implemented the BF promotion intervention? | Healthy Steps Specialists, Pediatricians, and Pediatric Nurse Practitioners
Comparator (Description) | No Healthy Steps intervention
Inclusion Criteria | | Exclusion Criteria | Mothers did not speak English or Spanish, too ill to make office visit within 4 wk, and others
Other Population Description | BF data only assessed in mothers who initiated BF | Setting | Hospital/clinic/home
Comments | Outcome data obtained via phone between 8 and 18 wks of age

CHARACTERISTICS | | | RCT | | | | Non-RCT
Intervention | | Control | | Intervention | | Control
No. Enrolled | | | 1021 | | 966 | | 1610 | | 1299
Mean Age | | | 20–29 ≥ 30 | 52% 33% | 20–30 ≥ 30 | 51% 34% | 20–31 ≥ 30 | 46% 42% | 20–32 ≥ 30 | 54% 34%
Birth weight <2500 g in total enrollment: | | | 7.9% | | 7.1% | | 6.4% | | 5.6%
No. Enrolled who initiated BF | | | 729 | | 683 | | 1297 | | 971
Range | metric:
Baseline education (<11 yr): | | | 15% | | 15% | | 15% | | 20%
Range | metric:
Duration of BF promotion
Duration of Followup (after the intervention stopped) | | | Up to 18 wk
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
nd | nd | nd | N | 10% | Y | Y | Y
List the variables that were adjusted for: | | | Site of enrollment, age of infant at interview, maternal, paternal, and infant characteristics
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Not possible to randomize all sites due to constraints on willingness of different practices to provide different services and other reasons

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Intervention | | | Control | | | Unadjusted | | | Adjusted
Outcome | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Initiated BF | Individual | Initiated BF
Continue to BF between 2 and 4 mo (RCT) | | 729 | 55.6% | | 683 | 54% | | | | 1.15 | 0.91–1.45
Continue to BF between 2 and 4 mo (non-RCT) | | 1297 | 57.1% | | 971 | 51.5% | | | ≤0.01 | 1.15 | 0.96–1.39
BF > 6 mo rate
Infant health outcomes
maternal health outcomes
Other outcome
AE: Other

APPLICABILITY | | | QUALITY
Subjects drawn from group practices, hospitals, and health maintenance organizations; 33% Medicaid; 20% Hispanic; 24% African American | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
No details on breastfeeding; method of randomization not described

Author | Mizuno | Year | 2004 | UI | 15841774

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Japan | N | February 1 2002 to March 31 2003 | Not stated

Type (Description) of BF promotion intervention | Mother-newborn skin-to-skin contact from birth till newborn stop suckling. Then, there is no contact between mother and infant until 24 hours after birth.
Who implemented the BF promotion intervention? | Midwife
Comparator (Description) | Routine care: no contact between mother and infant until 24 hours after birth
Inclusion Criteria | Full term and healthy newborns | Exclusion Criteria
Other Population Description | | Setting | Hospital
Comments | Babies are excluded from analysis if developmental or growth abnormality is diagnosed during follow up. All infants are fed formula for the first 24 hours of life.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 30 | | 30
Mean Age | | | 31.8 | | 30.6
Age Range | metric
Gestational Age: | | | 39.5 | | 39.5
Range | metric:
Baseline SES Measure: | | | ND | | ND
Range | metric:
Duration of BF promotion | | | 1-time >50min contact
Duration of Followup (after the intervention stopped) | | | 1 year | | 1 year
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Not specified | ND | N | Y | 3% | N | Y | N
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | 2 infants from the control group were excluded from the analysis due to paternal consent withdrawal at 2 d of age and a diagnosis of melena neonatorum at 3 d of age

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% Cl | P between
Individual | Group | Individual | Group
Exclusive BF rate | at the time of discharge | 30 | | 25 (83%) | 28 | | 24 (86%)
BF at 3 mo rate | Estimated from figure | | | 72% | | | 82%
BF at 6 mo rate | Estimated from figure | | | 60% | | | 28%
BF at 12 mo rate | Estimated from figure | | | 20% | | | 7%

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
BF duration | Not described (Months) | BF promotion | 30 | | 6.7 | 3.7 | 1.9 | 0.016
Control | 28 | | 4.8 | 2.5

Results Comments | Although the authors stated how “full”, “exclusive”, and “partial” breastfeeding were measured and defined in the method, it is unclear that what definition of “breastfeeding” of use in the analyses of breastfeeding duration

APPLICABILITY | | | QUALITY
| | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Fathers not in the delivery room, postpartum stay ≥ 4 d, infants not with mothers for 24 h post delivery and was fed formula (hospital policy), midwives in attendance to help babies latch on at the initial breastfeeding | | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Recruitment method was unclear. Breastfeeding definition in the analyses of breastfeeding duration was unclear.

Author | Muirhead | Year | 2006 | UI | 165369859

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Scotland | N | July 1997 to March 2002 | Government

Type (Description) of BF promotion intervention | Peer support plus normal breastfeeding support: Peer supporters visited participants at least once during the antenatal period. Peer support was available to women if they were breastfeeding on returning home from hospital after delivery and if the peer supporters were informed in time. After returning home from hospital, mothers were contacted by their peer supporters at least every 2 days or as often as required until day 28.
Who implemented the BF promotion intervention? | Peer supporters, experienced breastfeeding mothers known to the trial team and received training to gain the knowledge and skills necessary to provide appropriate support to women before and following childbirth. The training was initially 2 full days and 4 evening sessions with regular follow-up sessions where supporters presented case studies and reflected on their input. Each pair of peer supporters was given health professional supervision.
Comparator (Description) | Normal breastfeeding support: a community midwife for the first 10 days, health visitor after 10 days, breastfeeding support groups and breastfeeding workshops.
Inclusion Criteria | Women at 28 weeks of gestation from a general practice. | Exclusion Criteria | ND
Other Population Description | | Setting | Home
Comments | The authors stated that peer supporters had little or no contact with women in hospital, so that only hospital midwives helped mothers in both groups to initiate breastfeeding.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 112 | | 113
Mean Age | | | 28.5 | | 27.8
Age Range | metric | | 17–43 | | 16–40
Gestational Age: | | | ND | | ND
Range | metric:
Baseline SES Measure: | | | ND | | ND
Range | metric:
Duration of BF promotion | | | At least once during the antenatal period. At least every 2 days or as often as required until day 28 after mothers returned home.
Duration of Followup (after the intervention stopped) | | | 16 weeks postpartum | | 16 weeks postpartum
Comments: | Based on the reasons that mothers gave for not breastfeeding initiation, there were some premature babies and babies in special care (5.3% and 6.25 respectively)

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
In a block of 10, separated for each of 4 strata (primagravidae, previous formula feeder, previouslybreastfed <6 weeks, previous breastfed >6 weeks). | Y | Y | N/A (self-administered questionnaire) | 2.3 | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Based on the reported data, groups were similar at baseline, although limited baseline demographic data was reported.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RD (%) | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | Not considered as an “outcome” (see comment)
Exclusive BF at 6 weeks | No other feeding apart from breastfeeding | 110 | | 27 (24.1%) | 110 | | 24 (21.2%) | 2.9 | -8.1 to 13.8
Exclusive BF at 8 weeks | No other feeding apart from breastfeeding | 110 | | 23 (20%) | 110 | | 16 (14.2%) | 6.4 | -3.5 to 16.2
BF at 16 weeks | | 110 | | 26 (23.2%) | 110 | | 20 (17.7%) | 5.5 | -5.5 to 16.0
Exclusive BF at 16 weeks | No other feeding apart from breastfeeding | 110 | | 2 (1.8%) | 110 | | 0 | 1.8 | -0.7 to 4.2
No formula by 16 weeks | | 110 | | 16 (14.3%) | 110 | | 9 (8.0%) | 6.3 | -1.9 to 14.5

Results Comments | Based on the study design, the breastfeeding initiation rate was nothing or little to do with peer support intervention. Therefore, it is not included here as an “outcome”. 31 (54.5%) and 60 (63.1%) if women in the intervention and control group initiated breastfeeding, respectively (p=NS) Discrepancy noted: 97 (86% of intervention group) in Fig. 1 differed from 61 (54.5% of intervention group) in Tbl 2 received peer support.

APPLICABILITY | | QUALITY
Population recruited from a general practice | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Normal BF support: community midwife for the first 10 d, health visitor after 10 d, BF support groups and workshops; little demographic data on the mothers | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Peer support only available for women in the intervention group, who initiated breastfeeding.

Author | Noel-Weiss | Year | 2006 | UI | 16958717

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Canada | N | ND | ND

Type (Description) of BF promotion intervention | Prenatal breastfeeding workshop based on the theory of self-efficacy and on adult learning principles
Who implemented the BF promotion intervention? | The researchers
Comparator (Description) | Not described (no workshop)
Inclusion Criteria | Nulliparous women expecting a single child, an uncomplicated birth, and planning to breastfeed. Read and write in English and have a telephone. Mother-infant pair had to be discharged at the same time and be able to breastfeed without restriction. | Exclusion Criteria | None
Other Population Description | | Setting | Hospital
Comments

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | Total = 101
Mean Age | | | 30.2
Age Range | metric | | 17 – 42
Gestational Age: | | weeks | 39.77
Range | metric: | weeks | 36 – 42
Baseline SES Measure: | | | Family income >$70,000
Range | metric:
Duration of BF promotion | | | 2.5 hours
Duration of Followup (after the intervention stopped) | | | 8 weeks postpartum
Comments: | 6 women (randomized to the intervention group did not attend the workshop. High SES status

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Matching the sealed manila envelope with a sealed, sequentially numbered, opaque envelope containing the assignments | Y | Y | Y | 9 | N | Y | Y
List the variables that were adjusted for: | | | N
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | 2 dropped out for personal reasons, 2 did not remain in contact, and 6 had medical reasons for not remaining in the study.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc. (ITT analyses)

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF at 8 weeks | Exclusive breastfeeding by breast | 47 | | 33 (70%) | 45 | | 26 (58%) | | | 0.135
BF at 8 weeks | Exclusive by breast/some EBM*** | 47 | | 1 (2%) | 45 | | 0 | | | 0.135
BF at 8 weeks | Exclusive EBM* | 47 | | 0 | 45 | | 3 (7%) | | | 0.135
BF at 8 weeks | Almost exclusive | 47 | | 0 | 45 | | 0 | | | 0.135
BF at 8 weeks | High (one or less bottle of formula daily) | 47 | | 2 (4%) | 45 | | 5 (11%) | | | 0.135
BF at 8 weeks | Partial (>1 bottle of formula daily) | 47 | | 4 (9%) | 45 | | 1 (2%) | | | 0.135
BF at 8 weeks | Token feeding (breastfeeding for comfort and not for nutritive reasons) | 47 | | 0 | 45 | | 0 | | | 0.135
Bottle-feeding (weaned) | 47 | | 7 (15%) | 45 | | 10 (22%)

*** Exclusive by breast/some EBM = breastmilk by breast with no other liquids or solids except some bottles of EBM and possibly vitamins

* Exclusive EBM = all feeds are by bottle with EBM

RESULTS: Breastfeeding rate etc. (Actual workshop attendance analyses)

Outcome | Definition | BF promotion attendance | | | Nonattendance | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF at 8 weeks | Exclusive breastfeeding by breast | 41 | | 32 (78%) | 51 | | 27 (53%) | | | 0.005
BF at 8 weeks | Exclusive by breast/some EBM*** | 41 | | 2 (1%) | 51 | | 0 | | | 0.005
BF at 8 weeks | Exclusive EBM* | 41 | | 0 | 51 | | 3 (6%) | | | 0.005
BF at 8 weeks | Almost exclusive | 41 | | 0 | 51 | | 0 | | | 0.005
BF at 8 weeks | High (one or less bottle of formula daily) | 41 | | 2 (5%) | 51 | | 5 (10%) | | | 0.005
BF at 8 weeks | Partial (>1 bottle of formula daily) | 41 | | 4 (10%) | 51 | | 1 (2%) | | | 0.005
BF at 8 weeks | Token feeding | 41 | | 0 | 51 | | 0 | | | 0.005
Bottle-feeding (weaned) | 41 | | 2 (5%) | 51 | | 15 (29%)

RESULTS: Continuous measures (ITT analyses)

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
Number of days of breastfeeding at 8 weeks postpartum | days | BF promotion | 47 | | 50.4 | 14.2 | | 0.34
Control | 45 | | 49.9 | 14.5
Timing of first feeding | hour | BF promotion | 47 | | 2.81 | 6.89 | | 0.106
Control | 45 | | 5.44 | 8.54
Formula given in hospital | Number of bottles | BF promotion | 47 | | 2.68 | 6.53 | | NS
Control | 45 | | 4.07 | 5.72

RESULTS: Continuous measures (Actual workshop attendance analyses)

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
Number of days of breastfeeding at 8 weeks postpartum | days | BF promotion | 41 | | 54.0 | 9.3 | | 0.20
Control | 51 | | 47.1 | 16.7
Timing of first feeding | hour | BF promotion | 41 | | 2.95 | 7.37 | | NS
Control | 51 | | 5.02 | 8.1
Formula given in hospital | Number of bottles | BF promotion | 41 | | 1.63 | 3.18 | | 0.15
Control | 51 | | 4.75 | 7.51
Results Comments

APPLICABILITY | | QUALITY
High income, majority completed secondary education, 36% had cesarean section, 68% received free formula | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Subjects volunteered for the study; 87% intended to breastfeed before getting pregnant | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Workshop conducted by the same person

Author | O'Connor | Year | 2003 | UI | 12675164

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | Canada | Y (2 sites: A&B) | 1997-1999 | nd

Type (Description) of BF promotion intervention | 2 home visits post discharge (1^st^ visit ASAP, 2^nd^ visit within 10 d, some cases were delayed by a few days), thorough infant and postpartum assessment, referrals to other services if necessary
Who implemented the BF promotion intervention? | Public Health Nurse
Comparator (Description) | telephone call (but a home visit was made if a need was identified)
Inclusion Criteria | Primipara, singleton, vaginal delivery, discharged within 2 d, understand English, BF at time of discharge | Exclusion Criteria
Other Population Description | ≥ 35 wk gestation | Setting | Selected from 2 tertiary care hospitals in Ontario, Canada
Comments | Telephone group also received home visit if necessary.

CHARACTERISTICS | | | Home visit | | Telephone call
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 174 (A); 179 (B) | | 184 (A); 196 (B)
Mean Age | | | 26 (A); 28 (B) | | 28 (A); 27 (B)
Gestational age | metric | % 35–37 wk | 4% (A); 8% (B) | | 8% (A); 6% (B)
Baseline Health Measure:
Range | metric:
Baseline education Measure: completed postsecondary | | | 62% (A); 67% (B) | | 63% (A); 68% (B)
Range | metric:
Duration of BF promotion | | | 2 home visits
Duration of Followup (after the intervention stopped) | | | 6 mo
Comments: | Site A and B were significantly different from each other in mothers' education and GA

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random numbers | Y | Y | Y | 29% | Y | N | Y
List the variables that were adjusted for: | | | Duration of BF adjusted for site (A or B) and other significant variables in a Cox regression
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Site | Home visit | | | Telephone | | | Unadjusted
Outcome | Site | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate (BF at 2 wk) | A | 149 | | 130 (87.2%) | 167 | | 147 (87%)
B | 157 | | 141 (89.9%) | 165 | | 145 (87.9%)
BF at 4 wk | A | 129 | | 122 (94.6%) | 146 | | 130 (89%)
B | 140 | | 133 (95%) | 143 | | 136 (95.1%)
BF at 6 mo rate | A | 118 | | 69 (58.5%) | 129 | | 69 (53.5%)
B | 129 | | 77 (59.7%) | 133 | | 80 (60.2%)
Total number of infants with health problems (up to 4 weeks postpartum) | A | 167 | | 92 (55.1%) | 175 | | 86 (49.1%) | | | NS
B | 169 | | 86 (50.9) | 185 | | 110 (59.5%) | | | NS
Results Comments | Cox regression revealed no significant difference between Home visit and Telephone Screen (P=0.22). Does not appear that the Home visit is specifically targeted at BF support.

APPLICABILITY | | QUALITY
Low risk family that can be discharged within 2 d | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Mothers restricted to those who are fluent in the main language of the community where they live | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
29% lost-to-followup at 6 month

Author | Pisacane | Year | 2005 | UI | 16199676

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Nonrandomized, but Controlled Trial (subjects allocated to one of the two blocks of time) | Italy | N | October 1, 2002 to January 31, 2003 | nd

Type (Description) of BF promotion intervention | Fathers received a face-to-face, 40-min session about infant feeding and the difficulties sometimes associated with breastfeeding, such as fear of milk insufficiency; transitional lactation crisis, return to outside employment; and problems such as breast engorgement, mastitis, sore and inverted nipples, and breast refusal. They were taught how problems with lactation can occur and how it is possible to prevent and manage them. A leaflet with the main points of the session was provided to the fathers.
Who implemented the BF promotion intervention? | A midwife who was trained through the WHO-UNICEF 40-hour training course
Comparator (Description) | Fathers received a face-to-face 40-min training session about child care, such as accident prevention and vaccination, but discussion was focused on the health benefits of breast milk rather than the management of breastfeeding. A leaflet with the main points of the session was provided to the fathers.
Inclusion Criteria | All mother and father pairs of healthy, term, normal birth weight infants | Exclusion Criteria | Unmarried women, mothers who had decided to bottle feed, and parents whose infants were admitted to the ICU
Other Population Description | | Setting | Hospital
Comments

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 140 | | 140
Mean Age | | | nd | | nd
Age Range | metric | | 4% <20, 84% 20–35, 11% >35 | | 3% <20, 83% 20–35, 14% >35
Gestational Age: | | | Term | | Term
Range | metric:
Baseline SES Measure: | | Father's education >8 yr Mother's education >8 yr | 54% 61% | | 53% 60%
Range | metric:
Duration of BF promotion | | | 40 min
Duration of Followup (after the intervention stopped) | | | 12 mo
Comments: | During the 2 time blocks of the study period, 194 and 191 normal birth weight infants were born, respectively. The first consecutive 140 families who met the recruitment criteria were enrolled during each block of time. All of the families who were enrolled agreed to participate in the interview and in the training session.

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
N/a | nd | N | Y | 0 | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | The fathers of the newborn were allocated to the study groups according to the date of birth of their infants: those whose infants born in October and November were assigned to the intervention group and those whose infants were born in December and January constituted the control group. No modification in the care provided to the mothers and to the newborn was planned or implemented during the study period.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | At discharge from the hospital | 140 | | | 140
BF initiation rate | - Full | | | 127 (91%) | | | 124 (89%) | 1.02 | 0.9–1.1 | NS
BF initiation rate | - Complementary | | | 7 (5%) | | | 5 (4%) | 1.4 | 0.46–4.3 | NS
- Bottle | | | 6 (4%) | | | 11 (8%) | 0.5 | 0.2–1.4 | NS
BF at 6 mo rate | Full (exclusive+predominant) | | | 35 (25%) | | | 21 (15%) | 1.67 | 1.02–2.71 | <0.05
Complementary (any consumption of breast milk after the introduction) | | | 40 (33%) | | | 41 (34%) | 0.98 | 0.68–1.39 | NS
BF at 12 mo rate | Complementary | | | 27 (19%) | | | 16 (11%) | | | 0.09
Full BF at 6 mo rate | Among mothers who reported breastfeeding problems | 96 | | 23 (24%) | 89 | | 4 (4.5%) | | | <0.001
Among mothers who didn't report breastfeeding problems | 44 | | 12 (27%) | 51 | | 17 (33%) | | | NS
Results Comments | 69% and 64% of the mothers in the intervention and control group respectively reported problems and difficulties with lactation, but the type of problems and the frequency of breastfeeding interruption were significantly different between the groups.; - Perceived milk insufficiency and giving up breastfeeding due to problems with lactation were significantly more frequent among the mothers of the control group; - Significantly more mothers in the intervention group reported to have received support and relevant help with infant feeding from their partners.

APPLICABILITY | | QUALITY
Married parents | Factors reported in the study that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
x | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Exclusion of unmarried parents (an important subgroup in US) | Factors reported in the study that one is unlikely to encounter in US primary care | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
No apparent adjustment was made to account for the fact that the two interventions took place in two different time periods.

Author | Pugh | Year | 2001 | UI | 11508101

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
“Quasi experimental” | US | Y | ND | University

Type (Description) of BF promotion intervention | Breastfeeding Support Team (BST): Traditional educational support for breastfeeding, emphasized ways to decrease breast discomfort using positioning to decrease fatigue, and provided social support. This included a nurse visit during hospitalization and at least 3 home visits (during weeks 1, 2, and 4). Peer counselor also visited and provided telephone support twice weekly through week 8 and weekly through month 5.
Who implemented the BF promotion intervention? | A community health nurse and peer counselor
Comparator (Description) | Usual care: 1 hospital visit by a lactation consultant and up to 2 nurse home visits for infant assessment and care.
Inclusion Criteria | Women in the 2 study hospitals; receiving medical assistance low-income) | Exclusion Criteria | ND
Other Population Description | 100% low-income, 40% minority (30% African-American, 5% Latino-American, 5% other), 60% single, mostly young women | Setting | Hospital and home
Comments | This is a pilot study. Response rate 80%. Both groups received usual care.

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 10 | | 10
Mean Age | | | 23.8 | | 24.9
Age Range | metric
Gestational Age: | | | 39.1 | | 39.9
Range | metric:
Baseline SES Measure: | | Education (years) | 12.1 | | 12.5
Range | metric:
Duration of BF promotion | | | a nurse visit during hospitalization, >3 home visits; routine peer counselor visited and telephone supports
Duration of Followup (after the intervention stopped) | | | 5 months | | 5 months
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Not described | N/A | N | N | 0 | Y (only on matching factors) | Y | Y
List the variables that were adjusted for: | | | Women were matched on type of delivery, previous breastfeeding experience, and race.
Were statistical analyses appropriate? ^iv^ (Y/N) | | | N (no statistical method was described)
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | RD | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF at 5 mo rate | Not described | 10 | | 4 (40%) | 10 | | 1 (10%) | | | ND

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Baseline | Final | SD | Net difference | P between
Individual | Group
Maternal depressive symptoms | CES-D* (ranged 0–60) | BF promotion | 10 | | 13.3 | 5.9 | 9.1 | ND | ND
Control | 10 | | 12.8 | 12.6 | 17.2
Maternal fatigue | Three dimension scales of fatigue: tiredness, decreased concentration, and a physical feeling of fatigue (ranged 0–300) | BF promotion | 10 | | 143.1 | 18.8 | 28.2 | ND | ND
Control | 10 | | 125.8 | 43.5 | 43.6
Maternal Anxiety | Speilberger State Trait Anxiety Inventory (ranged 20–60) | BF promotion | 10 | | 29.2 | 30.8 | 10.1 | ND | ND
Control | 10 | | 31.8 | 35.3 | 16.2

* CES-D, Center for Epidemiologic Study-Depressive Symptomatology Scale

Results Comments | Unclear if breastfeeding rates from birth to less than 5 months were collected.

APPLICABILITY | | QUALITY
Low income, 40% minority, primarily young single women, large metropolitan community | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Wide | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Method of “quasi-experimental” was not described. Outcomes were all self-reported, so cannot blind women to the group assignments. Exclusivity of breastfeeding was unclear. Small sample size.

Author | Reeve | Year | 2004 | UI | 15063960

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
Non-RCT | UK | N | March to July 1999 | ND

Type (Description) of BF promotion intervention | Routine care plus a breastfeeding seminar: brainstorming, discussion of individual selection, investigation of strategies, and role-play. “Experiential learning” model.
Who implemented the BF promotion intervention? | The primary investigator (MD)
Comparator (Description) | Routine care: routine antenatal provision for receiving information about infant feeding. Parentcraft classes provided by district midwives and breastfeeding workshops offered within the hospital setting are available for those wanting to breastfeed.
Inclusion Criteria | All primiparous women attending antenatal clinic at a hospital for their 32 weeks check, during a 5-month period | Exclusion Criteria | ND
Other Population Description | | Setting | Hospital
Comments | 181 women approached and 73 agreed to participate

CHARACTERISTICS | | | Breastfeeding education | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 33 | | 40
Mean Age | | | ND | | ND
Age Range | metric | <20 years old | 6.1% | | 12.5%
Gestational Age: | | | ND | | ND
Range | metric:
Baseline SES Measure: | | Professional | 51.5% | | 50.0%
Range | metric:
Duration of BF promotion | | | 2 hours
Duration of Followup (after the intervention stopped) | | | 4 months postpartum
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
N/A | N/A | N | ND | 0 | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Yes
Comments | Non-random block allocation: Women were assigned to intervention and control groups before being approached based on the time of their appointment: those attending the clinic during a six week period in April–May 1999 were assigned to intervention group; those attending afterwards or before were assigned to the control group.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF education | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | Breastfeeding on day one (self-report) | 33 | | 26 (78.8%) | 40 | | 28 (72.5%) | | | NS
BF at 4 mo rate | Breastfeeding at 4 months (self-report) | 33 | | 16 (48.5%) | 40 | | 8 (20%) | | | 0.0099

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD/SE | Net difference | P between
Individual | Group
BF duration | | BF promotion
Control
Results Comments | High breastfeeding initiation rate in both groups.

APPLICABILITY | | QUALITY
| Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
60% of eligible subjects did not enroll in the study, small number of subjects selected from 1 hospital | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
“Breastfeeding” was self-reported and exclusivity was not defined. Non-randomized design although no statistically significant difference in baseline characteristics and SES (likely the study was not power to detect those differences). Unclear whether or not the outcome assessor was blinded.

Author | Ryser | Year | 2004 | UI | 15296584

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | N | nd | University

Type (Description) of BF promotion intervention | Best Start Program (education intervention): assess subjects' perceptions of BF; acknowledgement and reassurance; targeted educational messages; presented in 4 prenatal visits
Who implemented the BF promotion intervention? | researcher
Comparator (Description) | No intervention
Inclusion Criteria | ≥ 18 yr; English speaking, gestation early enough to allow 4 contacts; low income, intention to bottle feed or undecided | Exclusion Criteria | Intend to BF
Other Population Description | Sample from one physician's office | Setting | physician's office
Comments

CHARACTERISTICS | | | Best Start | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 26 | | 28
Mean Age | | | 25.3 ± 5.6 | | 22.6 ± 4.6
Age Range | metric | | 18–40 | | 18–36
Gestational Age: | | | nd | | nd
Range | metric:
Baseline SES Measure: | | | low income | | low income
Range | metric:
Duration of BF promotion | | | 4 prenatal visits
Duration of Followup (after the intervention stopped) | | | BF assessed via phone within 1 wk post delivery
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Subjects select a sealed envelope | nd | N | N | 0* | N | Y | Y
List the variables that were adjusted for: | | | nd
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | ?Discrepancy in text: “All 54 completed the study.” But only 53 had data on BF initiation.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
Exclusive BF initiation rate | No formula, 1-week postpartum telephone f/up | 23 | | 14 (61%) | 27 | | 4 (15%) | | | P<0.01

APPLICABILITY | | | QUALITY
Low income (90% eligible for Medicaid), | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Subjects recruited from one physician's practice, “nonprobability” sample | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Unadjusted results, small sample, non-blinded

Author | Schlickau | Year | 2005 | UI | ?

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | N | ND | ND

Type (Description) of BF promotion intervention | 1^st^ level: Prenatal breastfeeding education (PBE)- enhance knowledge, increase perception of benefits, and decrease perception of barriers to breastfeeding. 2^nd^ level: PBE plus commitment-to-breastfeed (PBE-CB)- a session involving the PBE intervention in which a selected group of participants formulated a specific plan for breastfeeding and committed to breastfeed for a certain length of time.
Who implemented the BF promotion intervention? | The researchers
Comparator (Description) | Usual care
Inclusion Criteria | Low-risk, primigravid Hispanic women in their 3^rd^ trimester who received care at the clinic. Normal breast and nipple exam, stable family and not planning to work outside the home for 6 months. | Exclusion Criteria | ND
Other Population Description | 85% emigrated from Mexico within the last 7 years; all preferred to speak Spanish rather than English. | Setting | Hospital
Comments | Health Promotion Model was chosen to guide to development of the intervention. Participants were referred to the researcher by the clinic's staff. 2^nd^ level of the intervention was administered to those who had completed the 1^st^ level during a previous clinic visit and who had been randomized to the Level 2 group at the time of enrollment. This is a pilot study. 32 women approached, 30 were recruited.

CHARACTERISTICS | | | Breastfeeding education | | | Control
CHARACTERISTICS | | | Individual level | | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
PBE | PBE-CB
No. Enrolled | | | 10 | 10 | | 10
Mean Age | | | 22
Age Range | metric | | 16–45
Gestational Age: | | | ND
Range | metric:
Baseline SES Measure: | | | ND
Range | metric:
Duration of BF promotion | | | PBE: 1 hr PBE+CB: 2 hrs
Duration of Followup (after the intervention stopped) | | | 45 days | | | 45 days
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
N | ND | N | ND | 17 | N | ND | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | | Control | | | Unadjusted
Outcome | Definition | No. Analyzed | | No. Events | | No. Analyzed | | No. Events | OR/RR | 95% CI | P between
PBE | PBE+CB | PBE | PBE+CB | Individual | Group
BF by 45 days | By 45 days | 9 | 9 | 33% | 56% | 7 | 29% | | | | ND

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
BF duration | days | PBE | 9 | | 23.1 | 15.9 | 6.3 | NS
BF duration | days | PBE+CB | 9 | | 31.1 | 16.2 | 14.3 | NS
Control | 7 | | 16.9 | 18.2
Results Comments | This is a pilot study. Underpowered.

APPLICABILITY | | | QUALITY
Primigravid, low-risk, Hispanic women, immigrants | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Small convenience sample | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Method of randomization not described. More controls were lost to follow-up. Total lost to follow-up 17%. Short follow-up period. Exclusivity of breastfeeding was unclear. Unclear whether the outcome assessors were blinded.

Schniedrova 2003 UI 14521822

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Intervention | Control Intervention
Mean age (range): Mean GA (range): Term Enrolled/Evaluate:: 1,104 / 1,019 Location: Czech Republic Sites: Multi: 9 sites Funding: government | Prospective study at 2 time points comparing infants from Baby Friendly hospitals with other hospitals; first questionnaire: 36 questions: education, marital status, decision on infant feeding, prenatal preparation, birth, breastfeeding support in the hospital, infant feeding practices at discharge; followup questionnaire at 6 mo: 51 questions; mothers randomly selected | Term, ≥ 2500 g; no postnatal complications, no multiple births | Hospitals with Baby-friendly hospital award | Other hospitals

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | 1,104 mothers completed initial interview; 1,109 mothers completed 6 mo interview; 5 Baby-friendly hospitals (625 mothers), 4 others (479 mothers) 93.5% of infants were BF exclusively at discharge; 23.1% of infants were BF exclusively at 6 mo; Duration of exclusive BF in both groups were comparable: Baby-friendly: 3.9 mo ± 1.92 SD Others: 3.90 mo ± 1.84 SD Actual numbers of the two groups at 6 mo was not reported. | A: strong, B: moderate, C: weak | A | B | C
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Selection | | x
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Study design | | | x
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Confounder | | | x
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Blinding | | | x
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Data collection | | | x
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Withdraw and dropout | x
Feeding modes, duration of exclusive BF Exclusive BF, supplemented BF, formula | ANOVA, F test, chi2; Method of randomization not reported; did not report control for characteristics differences between hospitals (baby-friendly vs. others) | | Analyses | | | x

Applicability

Study characteristics that one is likely to encounter in US primary care | Samples selected from large cities; pediatricians not trained in lactation management and counseling
Study characteristics that may limit the applicability to a US primary care population | 56% of the maternity units in the study had the Baby Friendly status
Overall assessment of applicability to US primary care (wide or narrow) | Narrow

Author | Wallace | Year | 2006 | UI

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | England | Y | 2001-2002 | Government

Type (Description) of BF promotion intervention | “hands off” approach to BF: advice about baby initiation of feeding, positioning and attachment
Who implemented the BF promotion intervention? | Midwives who received a 4-h workshop
Comparator (Description) | Usual care delivered by midwives who did not receive the 4-h workshop
Inclusion Criteria | Intend to BF, primiparous, GA>37wk, able to sit out of bed at time of first feed | Exclusion Criteria | c-section under general anesthesia
Other Population Description | | Setting | Hospital (not BFHI accredited)
Comments

CHARACTERISTICS | | | Breastfeeding promotion | | | | Control
Individual level | | Group level (if cluster or quasi-RCT) | | Individual level | | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 188 | | | | 182
Mean Age | | | <20 20–29 30–39 | 5% 50% 43% | | | <20 20–30 30–39 | 6% 52% 40%
Age Range | metric
Gestational Age: | | | >37wk | | | | >37wk
Range | metric:
Baseline SES Measure:
Range | metric:
Duration of BF promotion | | | Initial feeding only
Duration of Followup (after the intervention stopped) | | | 17 wk postpartum
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Telephone balanced block and computer | Y | Y | Y | 6% | N | Y | Y
List the variables that were adjusted for: | | | None
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
Exclusive BF rate at 17 wk | Breast milk and non-nutritive water feed | 174 | | 7 (4%) | 168 | | 7 (4.2%) | | | NS
Ever BF rate at 17 wk | | 173 | | 64 (37%) | 167 | | 66 (40%) | | | NS

APPLICABILITY | | | QUALITY
Hospitals did not have BFHI accreditation, postnatal care managed by midwives | | Study characteristics that one is likely to encounter in US primary care | x | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| | Study characteristics that may limit the applicability to a US primary care population | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
wide | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)

Author | Wilhelm | Year | 2006 | UI | 16700683

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | Yes | nd | Private

Type (Description) of BF promotion intervention | Motivational Interviewing (initial session at days 2 to 4, then at 2 and 6 wk as outpatient) with goal of decreasing ambivalence and resistance toward sustained breastfeeding.
Who implemented the BF promotion intervention? | Research nurse
Comparator (Description) | Usual care: a lactation consultant troubleshooting problems during the hospital stay and at each visit using the AAP's (2002) guide to breastfeeding
Inclusion Criteria | primiparous BF mothers | Exclusion Criteria | NICU, <37 wk GA, <2500 g, bilirubin 15 mg/dL
Other Population Description | Rural community | Setting | hospital
Comments | Convenience sample

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 37 | | 36
Mean Age | | | 25
Age Range | metric | SD | 4.5
Gestational Age: | | | 39.3
Range | metric: | SD | 1.1
Baseline SES Measure: | | <high school | 6.8%
>$40,000 | 45.8%
Duration of BF promotion | | | nd
Duration of Followup (after the intervention stopped) | | | 6 mo | | 6 mo
Comments: | Intervention group has higher BF self-efficacy scores (P=0.001); paper did not report baseline data stratified by intervention and control; mean age = 25 (SD 4.5); mean GA = 39.3 wk (SD 1.1)

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
Random number | nd | N | N | 3% | Y | N | N
List the variables that were adjusted for: | | | Baseline BF self-efficacy, length of time before returning to work
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Motivational Interviewing trained nurse administered intervention; non-motivational trained nurse administered control

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | Events | No. Analyzed | | Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF at 6 mo rate | | 36 | | 32% | 35 | | 25%

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD | Net difference | P between
Individual | Group
BF duration | days | BF promotion | 36 | | 98.1 | 75.2 | Adjusted mean difference = 12 | NS
Control | 35 | | 80.7 | 71.9
Results Comments | One site reported the practice of motivational interviewing might not have been consistent because the formal training was too complex.

APPLICABILITY | | | QUALITY
Rural community | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Convenience sample | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Convenience sample, inadequate reporting of results

Author | Wolfberg | Year | 2004 | UI | 15467529

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) | US | N | March 2001 to August 2002 | Government

Type (Description) of BF promotion intervention | Breastfeeding classes for expectant fathers: Every 2 weeks in a group of 4 to 12. Nondidactic, informal environment, and use of a variety of teaching media. Core information was designed to educate the expectant fathers that breast milk is the best nutritional choice for their child and to help them develop the skill that are necessary to communicate that to their partner.
Who implemented the BF promotion intervention? | A peer classroom facilitator: easygoing and engaging, knowledgeable without being overbearing, black, and who was a father himself Expected fathers
Comparator (Description) | Control class (baby care and safety): Topics included car seat use, fire safety, lead-exposure prevention, sleeping positions, and bath safety, taught by the same facilitator. Similar media were used.
Inclusion Criteria | Partner of the women who sought prenatal care in the hospital | Exclusion Criteria | See comments
Other Population Description | Expectant fathers. 80% Black | Setting | Hospital
Comments | 567 pregnant women were approached and 59 couples completed the trial. Attrition reasons: refusal (24%), loss to follow-up during the prenatal period (36%), the mothers lack of involvement with the father of her pregnancy (8%), the fathers' refusal to participate (11%), and the fathers' failure to attend the study class after enrolling for the study (9%). Women who were excluded from the study were more likely to receive welfare (36% vs. 19%) and were less likely to be employed (38% vs. 61%) than the women in the study

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled | | | 27 | | 32
Mean Age | | | ND | | ND
Age Range | metric
Gestational Age: | | | ND | | ND
Range | metric:
Baseline SES Measure: | | < a high school education
Baseline SES Measure: | | - fathers | 22% | | 27%
Baseline SES Measure: | | - mothers | 30% | | 25%
Baseline SES Measure:
Baseline SES Measure: | | Employed
Baseline SES Measure: | | - fathers | 85% | | 70%
- mothers | 59% | | 63%
Mothers enrolled in WIC program | 78% | | 81%
Range | metric:
Duration of BF promotion | | | 2 classes, 2-hour for each class and 2 weeks apart
Duration of Followup (after the intervention stopped) | | | 8 weeks | | 8 weeks
Comments: | Low-income, minority

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
ND | N | N | ND | 3% | Y | Y | Y
List the variables that were adjusted for: | | | Mother breastfed previously, mother were breastfed as an infant, mother plans to breastfeed for first month, mother lives with father, mother's mother thinks baby should be breastfed, mother believes her partner thinks her baby should be breastfed, or father would like baby to be breastfed
Were statistical analyses appropriate? ^iv^ (Y/N) | | | Y
Comments | Power calculation was performed: 230 women were needed to detect a 50% increase in breastfeeding duration with a power of 0.8. Therefore, this study is clearly underpowered.

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR | 95% CI | P between | OR/RR | 95% CI | P between
Individual | Group | Individual | Group
BF initiation rate | Self-report by the mothers | 27 | | 20 (74%) | 32 | | 13 (41%) | | | 0.02
BF at 8 weeks | Self-report by the mothers | 26 | | 9 (35%) | 31 | | 6 (19%) | | | 0.13

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Baseline | Final | Change | P Within | Net Change | P between
Individual | Group
BF duration | | BF promotion
Control

Results Comments | The following paternal characteristics are associated with an increased incidence of breastfeeding initiation in the study: mother plans to breastfeed for first month (p=0.004), the baby's maternal grandmother's belief that the baby should be breastfed (p=0.03), mother believed her partner thinks her baby should be breastfed (p=0.002), and father's belief that the baby should be breastfed (p=0.03)

APPLICABILITY | | | QUALITY
Low-income, minority, expectant fathers | | Study characteristics that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
Highly selected sample; ~90% of eligible subjects did not participate | | Study characteristics that may limit the applicability to a US primary care population | x | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors.
Narrow | Overall assessment of applicability to US primary care (wide or narrow) | | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)
Method of randomization was unclear. No data on the blinding of outcome assessors. Exclusivity of breastfeeding was unclear.