# Appendix B. Data Abstraction Forms

Evidence Table Template

Author | | Year | | Ref ID | | UI | | Reviewer

Study Design (from perspective of BF intervention) | Country | Multicenter? (Y/N) | Calendar Years of study | Funding Source
RCT (subjects were randomized) Cluster-RCT (subjects clustered within centers/areas were randomized) Quasi-RCT (centers or caregivers were randomized)

Type (Description) of BF promotion intervention
Who implemented the BF promotion intervention?
Comparator (Description)
Inclusion Criteria | | Exclusion Criteria
Other Population Description | | Setting
Comments

CHARACTERISTICS | | | Breastfeeding promotion | | Control
Individual level | Group level (if cluster or quasi-RCT) | Individual level | Group level (if cluster or quasi-RCT)
No. Enrolled
Mean Age
Age Range | metric
Gestational Age:
Range | metric:
Baseline SES Measure:
Range | metric:
Duration of BF promotion
Duration of Followup (after the intervention stopped)
Comments:

QUALITY ISSUES

Method of randomization^i^ | Adequate allocation concealment^ii^ (Y/N/nd) | Intention to treat? (Y/N) | Outcome assessors blinded? (Y/N) | Loss to followup (%) | Were the results adjusted? (Y/N) | Were groups similar at baseline? (Y/N) | Recruitment method appropriate^iii^? (Y/N)
List the variables that were adjusted for:
Were statistical analyses appropriate? ^iv^ (Y/N)
Comments

i If cluster RCT, method used to generate the random allocation sequence, including details of any restriction (eg blocking, stratification, matching)

ii If cluster RCT, method used to implement the random allocation sequence, specifying that allocation was based on clusters rather than individuals and clarifying whether the sequence was concealed until interventions were assigned

iii Appropriate consecutive or randomized

iv If cluster RCT, Statistical methods used to compare groups for primary outcome(s) indicating how clustering was taken into account; methods for additional analyses, such as subgroup analyses and adjusted analyses

RESULTS: Breastfeeding rate etc.

Outcome | Definition | BF promotion | | | Control | | | Unadjusted | | | Adjusted
Outcome | Definition | No. Analyzed | | No. Events | No. Analyzed | | No. Events | OR/RR** | 95% CI** | P between | OR/RR** | 95% CI** | P between
Individual | Group | Individual | Group
BF initiation rate
BF > 3 mo rate
BF > 6 mo rate
Infant health outcomes**
maternal health outcomes**
Other outcome**
AE: Other**

** Duplicate one row per outcome. Replace “Other**” with actual Outcome and “OR/RR**” with actual metric and “95% CI**” with SE, if necessary

RESULTS: Continuous measures

Outcome | Definition (units) | Group | No. Analyzed | | Final | SD/SE** | Net difference | P between
Individual | Group
BF duration | | BF promotion
Control
Other** | | BF promotion
Control
Other** | | BF promotion
Control

** Replace “Other**” with actual Outcome and “SD/SE**” with actual metric

Results Comments

APPLICABILITY | | QUALITY
| Factors reported in the study that one is likely to encounter in US primary care | | A Good quality: Prospective, no obvious biases or reporting errors, <20% dropout, complete reporting of data. Must be RCT or cluster RCT.
| | | B Fair quality: Problems with study/paper unlikely to cause major bias. Must be RCT, cluster RCT, or non-randomized, controlled study.
| Factors reported in the study that one is unlikely to encounter in US primary care | | C Poor quality: Prospective or retrospective. Cannot exclude possible significant biases. Poor methods, incomplete data, reporting errors. All pre- and post-trials were rated C.
| Overall assessment of applicability to US primary care (wide or narrow) | If Quality is rated B or C, what are the limiting factors? (i.e., incomplete data, errors in analysis, definitions not clear, poor follow-up, dropouts)

Evidence Table Template, Observational Studies

Author, year [UI#]

Study characteristics | Study design and follow-up duration | Eligibility criteria | Breastfeeding promotion Intervention | Control Intervention
Mean age (range): Mean GA (range): Enrolled/Evaluate: Location: Sites: Single/Multi Funding:

Outcome Definition | Statistical analyses and confounders adjusted | Results | Bias/limitations Comments
| | | A: strong, B: moderate, C: weak | A | B | C
| | | Selection
| | | Study design
| | | Confounder
| | | Blinding
| | | Data collection
| | | Withdraw and dropout
| | | Analyses
| | | Intervention integrity

Applicability

Study characteristics that one is likely to encounter in US primary care
Study characteristics that may limit the applicability to a US primary care population
Overall assessment of applicability to US primary care (wide or narrow)