# Appendix A. MEDLINE® Search Strategy

## Human and Animal Search 1950 to January week 5 2007

# | Search History | Results
1 | infant nutrition.mp. or exp MIlk, Human/ | 23820
2 | human milk.mp. | 5763
3 | (human adj2 milk).tw. | 6370
4 | breast milk.mp. | 5384
5 | breastmilk.mp. | 346
6 | breast feeding.mp. | 20338
7 | breastfeeding.mp. | 5655
8 | breastfeed$.mp. | 5808
9 | breast fed.mp. | 3641
10 | breastfed.mp. | 1514
11 | (breast adj2 fed).tw. | 3822
12 | exp lactation/ | 25946
13 | (lactating or lactation).mp. | 36065
14 | or/1–13or/1–13 | 73052
15 | limit 14 to english language | 59770
16 | follow-up studies/ | 330722
17 | (follow-up or followup).tw. | 340787
18 | exp Case-Control Studies/ | 335140
19 | (case adj20 control).tw. | 45809
20 | exp Longitudinal studies/ | 549100
21 | longitudinal.tw. | 69276
22 | exp Cohort Studies/ | 595207
23 | cohort.tw. | 86811
24 | (random$ or rct).tw. | 358919
25 | exp randomized controlled trials/ | 46670
26 | exp random allocation/ | 56703
27 | exp double-blind method/ | 89226
28 | exp single-blind method/ | 10537
29 | randomized controlled trial.pt. | 228503
30 | clinical trial.pt. | 431474
31 | controlled clinical trials/ | 3302
32 | (clin$ adj trial$).tw. | 102676
33 | ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. | 85997
34 | exp PLACEBOS/ | 25721
35 | placebo$.tw. | 99472
36 | exp Research Design/ | 213290
37 | exp Evaluation Studies/ | 581017
38 | exp Prospective Studies/ | 214377
39 | exp Comparative Study/ | 0
40 | or/16–39 | 2082884
41 | 15 and 40 | 10598
42 | limit 41 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or interview or lectures or legal cases or legislation or letter or news or newspaper article or overall or patient education handout or periodical index) | 368
43 | limit 41 to comment and (letter or editorial).pt. | 109
44 | 41 not (42 or 43) | 10230
45 | limit 44 to (“review” or “systematic review”) [Limit not valid in: Ovid MEDLINE(R); records were retained] | 717
46 | limit 44 to yr=“2001 - 2007” | 3915