# Reference List

(1) Pediatric Nutrition Handbook. 5th ed. Elk Grove, IL: American Academy of Pediatrics; 2004.
(2) U.S.Department of Health and Human Services. Healthy People 2010: Conference Edition 28. Washington, DC: U.S. Government Printing Office; 2000.
(3) Li R, Darling N, Maurice E, Barker L, Grummer-Strawn LM. Breastfeeding rates in the United States by characteristics of the child, mother, or family: the 2002 National Immunization Survey. Pediatrics. January. 2005;115(1):e31-e37. [pmid: 15579667].
(4) Ip S, Chung M, Raman G et al. Breastfeeding and Maternal and Infant Health Outcomes in Developed Countries. Rockville, MD: Agency for Healthcare Research and Quality; 2007 Apr 20. Report No.: 153.
(5) Gartner LM, Morton J, Lawrence RA, et al. Breastfeeding and the use of human milk. Pediatrics. February. 2005;115(2):496-506. [pmid: 15687461].
(6) World Health Organization. Baby-friendly hospital initiative (BFHI) 26. Geneva: World Health Organization; 2004.
(7) Philipp BL, Merewood A, Miller LW, et al. Baby-friendly hospital initiative improves breastfeeding initiation rates in a US hospital setting 25. Pediatrics. September. 2001;108(3):677-81. [pmid: 11533335].
(8) Cohen R, Mrtek MB. The impact of two corporate lactation programs on the incidence and duration of breast-feeding by employed mothers. Am J Health Promot. July. 1994;8(6):436-41. [pmid: 10147273].
(9) Shealy KR, Li R, Benton-Davis S, Grummer-Strawn LM. The CDC Guide to Breastfeeding Interventions 27. Atlanta: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention; 2005.
(10) Guise J, Palda V, Westhoff C, Chan B, Helfand M, Lieu T. The effectiveness of primary care based interventions to promote breastfeeding: a systematic evidence review and meta-analysis for the U.S. Preventive Services Task Force. 10050. Agency for Healthcare Research and Quality 2003;Available at: URL: www.preventiveservices.ahrq.gov.
(11) U.S.Preventive Services Task Force (USPSTF). Counseling to Promote Breastfeeding. 10053. Guide to Clinical Preventive Services, 3rd Edition: Periodic Updates 2003.
(12) Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials.[see comment] 10054. JAMA. February 1. 1995;273(5):408-12. [pmid: 7823387].
(13) Britton C, McCormick FM, Renfrew MJ, Wade A, King SE. Support for breastfeeding mothers.[update of Cochrane Database Syst Rev. 2002;(1):CD001141; PMID: 11869593]. [Review][131 refs]. Cochrane Database of Systematic Reviews 2007;(1):CD001141.
(14) Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process 10052. Am J Prev Med. April. 2001;20(3 Suppl):21-35. [pmid: 11306229].
(15) DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. September. 1986;7(3):177-88. [pmid: 3802833].
(16) Higgins JP, Whitehead A, Turner RM, Omar RZ, Thompson SG. Meta-analysis of continuous outcome data from individual patients. Stat Med. August 15. 2001;20(15):2219-41. [pmid: 11468761].
(17) Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. September 6. 2003;327(7414):557-60. [pmid: 12958120].
(18) Berkey CS, Hoaglin DC, Mosteller F, Colditz GA. A random-effects regression model for meta-analysis. Stat Med. February 28. 1995;14(4):395-411. [pmid: 7746979].
(19) Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. September 15. 2003;22(17):2693-710. [pmid: 12939780].
(20) Anderson AK, Damio G, Young S, Chapman DJ, Perez-Escamilla R. A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community.[see comment]. Archives of Pediatrics & Adolescent Medicine. September. 2005;159(9):836-41. [pmid: 16143742].
(21) Bonuck KA, Trombley M, Freeman K, McKee D. Randomized, controlled trial of a prenatal and postnatal lactation consultant intervention on duration and intensity of breastfeeding up to 12 months. Pediatrics. December. 2005;116(6):1413-26. [pmid: 16322166].
(22) Bonuck KA, Freeman K, Trombley M. Randomized controlled trial of a prenatal and postnatal lactation consultant intervention on infant health care use. Archives of Pediatrics & Adolescent Medicine. September. 2006;160(9):953-60. [pmid: 16953019].
(23) Carfoot S, Williamson PR, Dickson R. The value of a pilot study in breast-feeding research. Midwifery. June. 2004;20(2):188-93. [pmid: 15177863].
(24) Carfoot S, Williamson P, Dickson R. A randomised controlled trial in the north of England examining the effects of skin-to-skin care on breast feeding.[see comment]. Midwifery. March. 2005;21(1):71-9. [pmid: 15740818].
(25) Coutinho SB, de Lira PI, de Carvalho LM, Ashworth A. Comparison of the effect of two systems for the promotion of exclusive breastfeeding. Lancet. September 24. 2005;366(9491):1094-100. [pmid: 16182897].
(26) Finch C, Daniel EL. Breastfeeding education program with incentives increases exclusive breastfeeding among urban WIC participants. Journal of the American Dietetic Association. July. 2002;102(7):981-4. [pmid: 12146564].
(27) Forster D, McLachlan H, Lumley J, Beanland C, Waldenstrom U, Amir L. Two mid-pregnancy interventions to increase the initiation and duration of breastfeeding: a randomized controlled trial. Birth. September. 2004;31(3):176-82. [pmid: 15330879].
(28) Henderson A, Stamp G, Pincombe J. Postpartum positioning and attachment education for increasing breastfeeding: a randomized trial. Birth. December. 2001;28(4):236-42. [pmid: 11903211].
(29) Howard CR, Howard FM, Lanphear B, et al. Randomized clinical trial of pacifier use and bottle-feeding or cupfeeding and their effect on breastfeeding. Pediatrics. March. 2003;111(3):511-8. [pmid: 12612229].
(30) Kramer MS, Barr RG, Dagenais S, et al. Pacifier use, early weaning, and cry/fuss behavior: a randomized controlled trial. JAMA. July 18. 2001;286(3):322-6. [pmid: 11466098].
(31) Labarere J, Bellin V, Fourny M, Gagnaire JC, Francois P, Pons JC. Assessment of a structured in-hospital educational intervention addressing breastfeeding: a prospective randomised open trial. BJOG: An International Journal of Obstetrics & Gynaecology. September. 2003;110(9):847-52. [pmid: 14511968].
(32) Labarere J, Gelbert-Baudino N, Ayral AS, et al. Efficacy of breastfeeding support provided by trained clinicians during an early, routine, preventive visit: a prospective, randomized, open trial of 226 mother-infant pairs. Pediatrics. February. 2005;115(2):e139-e146. [pmid: 15687421].
(33) McKeever P, Stevens B, Miller KL, et al. Home versus hospital breastfeeding support for newborns: a randomized controlled trial. Birth. December. 2002;29(4):258-65. [pmid: 12431265].
(34) Mizuno K, Mizuno N, Shinohara T, Noda M. Mother-infant skin-to-skin contact after delivery results in early recognition of own mother's milk odour.[see comment]. Acta Paediatrica. December. 2004;93(12):1640-5. [pmid: 15841774].
(35) Muirhead PE, Butcher G, Rankin J, Munley A. The effect of a programme of organised and supervised peer support on the initiation and duration of breastfeeding: a randomised trial.[see comment]. British Journal of General Practice. March. 2006;56(524):191-7. [pmid: 16536959].
(36) Ryser FG. Breastfeeding attitudes, intention, and initiation in low-income women: the effect of the best start program. Journal of Human Lactation. August. 2004;20(3):300-5. [pmid: 15296584].
(37) Schlickau J, Wilson M. Development and testing of a prenatal breastfeeding education intervention for Hispanic women. Journal of Perinatal Education. Fall. 2005;14(4):24-35. [pmid: 17273450].
(38) Wallace LM, Dunn OM, Alder EM, Inch S, Hills RK, Law SM. A randomised-controlled trial in England of a postnatal midwifery intervention on breast-feeding duration. Midwifery. September. 2006;22(3):262-73. [pmid: 16380197].
(39) Wilhelm SL, Stepans MB, Hertzog M, Rodehorst TK, Gardner P. Motivational interviewing to promote sustained breastfeeding. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. May. 2006;35(3):340-8.
(40) Wolfberg AJ, Michels KB, Shields W, O'Campo P, Bronner Y, Bienstock J. Dads as breastfeeding advocates: results from a randomized controlled trial of an educational intervention. American Journal of Obstetrics & Gynecology. September. 2004;191(3):708-12. [pmid: 15467529].
(41) Kramer MS, Chalmers B, Hodnett ED, et al. Promotion of Breastfeeding Intervention Trial (PROBIT): a randomized trial in the Republic of Belarus 10046. JAMA. January 24. 2001;285(4):413-20. [pmid: 11242425].
(42) Lavender T, Baker L, Smyth R, Collins S, Spofforth A, Dey P. Breastfeeding expectations versus reality: a cluster randomised controlled trial. BJOG: An International Journal of Obstetrics & Gynaecology. August. 2005;112(8):1047-53. [pmid: 16045516].
(43) Ekstrom A, Nissen E. A mother's feelings for her infant are strengthened by excellent breastfeeding counseling and continuity of care. Pediatrics. August. 2006;118(2):e309-e314. [pmid: 16882775].
(44) Ekstrom A, Widstrom AM, Nissen E. Does continuity of care by well-trained breastfeeding counselors improve a mother's perception of support?. Birth. June. 2006;33(2):123-30. [pmid: 16732777].
(45) McLeod D, Pullon S, Benn C, et al. Can support and education for smoking cessation and reduction be provided effectively by midwives within primary maternity care?. Midwifery. March. 2004;20(1):37-50. [pmid: 15020026].
(46) Chertok IR, Shoham-Vardi I, Hallak M. Four-month breastfeeding duration in postcesarean women of different cultures in the Israeli Negev. Journal of Perinatal & Neonatal Nursing. April. 2004;18(2):145-60. [pmid: 15214252].
(47) Chertok IR. Breast-feeding initiation among post-Caesarean women of the Negev, Israel. British Journal of Nursing. February 23. 2006;15(4):205-8. [pmid: 16603986].
(48) Pugh LC, Milligan RA, Brown LP. The breastfeeding support team for low-income, predominantly-minority women: a pilot intervention study. Health Care for Women International. July. 2001;22(5):501-15. [pmid: 11508101].
(49) Reeve JR, Gull SE, Johnson MH, Hunter S, Streather M. A preliminary study on the use of experiential learning to support women's choices about infant feeding. European Journal of Obstetrics, Gynecology, & Reproductive Biology. April 15. 2004;113(2):199-203.
(50) Cattaneo A, Buzzetti R. Effect on rates of breast feeding of training for the baby friendly hospital initiative. BMJ. December 8. 2001;323(7325):1358-62. [pmid: 11739226].
(51) Gau ML. Evaluation of a lactation intervention program to encourage breastfeeding: a longitudinal study. International Journal of Nursing Studies. May. 2004;41(4):425-35. [pmid: 15050853].
(52) Schneidrova D, Mullerova D, Janout V, Paulova M, Kudlova E. Impact of breast-feeding promotion on infant feeding in the Czech Republic. Journal of Nutrition Education & Behavior. September. 2003;35(5):228-35. [pmid: 14521822].
(53) Dulon M, Kersting M, Bender R. Breastfeeding promotion in non-UNICEF-certified hospitals and long-term breastfeeding success in Germany.[see comment]. Acta Paediatrica. June. 2003;92(6):653-8. [pmid: 12856972].
(54) Broadfoot M, Britten J, Tappin D, MacKenzie J. The Baby Friendly Hospital Initiative and breast feeding rates in Scotland. Archives of Disease in Childhood Fetal and Neonatal Edition 2005;2005 Mar; 90(2):F114–F116.
(55) Bosnjak AP, Batinica M, Hegedus-Jungvirth M, Grguri J, Bozikov J. The effect of baby friendly hospital initiative and postnatal support on breastfeeding rates—Croatian experience. Collegium Antropologicum. June. 2004;28(1):235-43. [pmid: 15636080].
(56) Boulvain M, Perneger TV, Othenin-Girard V, Petrou S, Berner M, Irion O. Home-based versus hospital-based postnatal care: a randomised trial. BJOG: An International Journal of Obstetrics & Gynaecology. August. 2004;111(8):807-13. [pmid: 15270928].
(57) Johnston BD, Huebner CE, Tyll LT, Barlow WE, Thompson RS. Expanding developmental and behavioral services for newborns in primary care; Effects on parental well-being, practice, and satisfaction. American Journal of Preventive Medicine. May. 2004;26(4):356-66. [pmid: 15110063].
(58) Johnston BD, Huebner CE, Anderson ML, Tyll LT, Thompson RS. Healthy steps in an integrated delivery system: child and parent outcomes at 30 months. Archives of Pediatrics & Adolescent Medicine. August. 2006;160(8):793-800. [pmid: 16894077].
(59) Minkovitz C, Strobino D, Hughart N, Scharfstein D, Guyer B. Healthy Steps Evaluation Team. Early effects of the healthy steps for young children program. Archives of Pediatrics & Adolescent Medicine. April. 2001;155(4):470-9. [pmid: 11296075].
(60) O'Connor KO, Mowat DL, Scott HM, Carr PA, Dorland JL, Young Tai KF. A randomized trial of two public health nurse follow-up programs after early obstetrical discharge: an examination of breastfeeding rates, maternal confidence and utilization and costs of health services. Canadian Journal of Public Health. March. 2003;Revue(2):98-103.
(61) Chapman DJ, Damio G, Young S, Perez-Escamilla R. Effectiveness of breastfeeding peer counseling in a low-income, predominantly Latina population: a randomized controlled trial. Archives of Pediatrics & Adolescent Medicine. September. 2004;158(9):897-902. [pmid: 15351756].
(62) Noel-Weiss J, Rupp A, Cragg B, Bassett V, Woodend AK. Randomized controlled trial to determine effects of prenatal breastfeeding workshop on maternal breastfeeding self-efficacy and breastfeeding duration. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. September. 2006;35(5):616-24.
(63) Pisacane A, Continisio GI, Aldinucci M, D'Amora S, Continisio P. A controlled trial of the father's role in breastfeeding promotion. Pediatrics. 2005;116:e494-e498. [pmid: 16199676].