# Limitations

This is a systematic review of primary care initiated interventions to promote and support breastfeeding. It is not always straightforward to determine if some of the interventions in the studies reviewed were indeed primary care initiated (e.g., some of the peer counseling interventions). We erred on the conservative side and included those studies in this review as long as there was a tangential hint that the health care system was involved. We included a Cochrane systematic review in this report but we did not reassess the individual studies within the review. Even though we have assessed the reporting quality of this systematic review, we cannot reliably know the validity of the reported summary data without knowing the details of the primary studies.

Studies included in our meta-analyses are heterogeneous in many aspects: different combinations of intervention components and background social support, different health care systems defining “usual” or “routine” care, different timing and intensities of the interventions, and diverse study populations. These sources of heterogeneity limited the validity and interpretability of the pooled estimates.

We performed subgroup analyses on formal/structured breastfeeding education, professional support, and lay support aiming to segregate the effects of different components of breastfeeding interventions. However, one should not interpret the observed effects as the “independent” effects of these intervention components on breastfeeding initiation and duration. This is because several components were often combined in the breastfeeding interventions. Our analyses only compared the interventions with a specific component to those without it. Other components in the intervention and the control groups may not be comparable in our meta-analyses. The previous meta-analyses attempted to examine the independent effects of different intervention components (education, support, or written materials) by using meta-regression. ^10^ However, we question the implicit assumption in this analysis that different intervention components are independent. The lack of data precluded us from performing a more appropriate analysis by incorporating interaction terms in the regression model.