# Results

## Search Results

Our search yielded 4,877 abstracts, of which 4,110 were rejected after initial screening using very broad inclusion/exclusion criteria. A second phase abstract screening using the formal criteria rejected additional 645 abstracts. One hundred seventy articles were retrieved for full text examination. The following studies met our inclusion/exclusion criteria: 21 RCTs, ^20^ – ^40^ two clustered RCTs, ^41,^ ^42^ two quasi-RCTs in three publications, ^43^ – ^45^ four controlled, non-randomized studies in four publications ^46^ – ^49,^ ^63^ two before-and-after experimental studies (BFHI only), ^50,^ ^51^ four prospective observational studies with concurrent or historical control (BFHI only), ^52^ – ^55^ , and one systematic review. ^13^ Eighteen studies were of good or fair quality; 18 studies were of poor quality. (Figure 2)

Figure 1. Analytic framework for the effect of interventions to promote breastfeeding

Figure 2. Study Eligibility Flow Chart

We also identified four studies (in five publications ^56^ – ^60^ ) with interventions that did not explicitly aim to promote breastfeeding. Nevertheless, they reported breastfeeding, maternal, and/or infant health outcomes. These studies are summarized in appendix H, but they are not included in our analyses.

## Results by Key Questions

### 1. What are the effects of interventions to promote and support breastfeeding, in terms of short- and long-term child and maternal health outcomes?

Three randomized controlled trials (RCTs) in four publications, ^20^ – ^22,^ ^41^ and one quasi-experimental study provided answers to this question. ^48^ One was rated good, ^41^ two were rated fair, ^20^ – ^22^ and one was rated poor quality. ^48^ One study was conducted in Belarus. ^41^ Three studies were conducted in low income populations in the United States. ^20^ – ^22,^ ^48^ Results from the four studies could not be combined in a meta-analysis because the interventions were not comparable.

Kramer 2001 was a cluster RCT of 34 maternal hospitals and associated polyclinics with a total of 17,046 mother-infant pairs from urban and rural areas in the Republic of Belarus (PROBIT). ^41^ The intervention was modeled on the Baby-Friendly Initiative of the World Health Organization and United Nations Children's Fund, which emphasizes assistance with initiating and maintaining breastfeeding and lactation and postnatal breastfeeding support. Compared to infants in the control group, the study found that infants in the intervention group were more likely to be exclusively breastfed at 3 months (43.3% vs. 6.4%; P<0.001) and 6 months (7.9% vs. 0.6%; P=0.01), and had a significant reduction in the risk of one or more gastrointestinal infections (9.1% vs. 13.2%; adjusted OR 0.60; 95%CI 0.40–0.91) and atopic dermatitis (3.3% vs. 6.3%; adjusted OR 0.54; 95%CI 0.31–0.95), but no significant reduction in respiratory tract infection. This study was rated good quality. However, the applicability of this study to the US setting is uncertain. Belarus had a postpartum hospital stay of 6 to 7 days, an obligatory 3-year maternity leave policy, no day care, and formulas that could cost 20 percent of an average monthly salary.

Bonuck 2005 was an RCT with a total of 382 mother-infant pairs from a low income (57% Medicaid), largely Hispanic (57%) or African American (36%) population. ^21,^ ^22^ The intervention was a series of hospital and home visits by two study lactation consultants. In addition to addressing issues specifically concerning breastfeeding, the study lactation consultants also helped the mothers to garner support from families, schools, workplaces, and health care providers. The study found that the ever breastfeeding rate at 5 months was higher in the intervention group compared to control (53% vs. 39%, P < 0.028). For the infants, there were no significant differences between the two groups in the risk of gastrointestinal illnesses, respiratory tract diseases, or otitis media. However, in a subgroup analysis of infants without Medicaid, infants of the intervention group had fewer otitis media related visits than control (P ≤ 0.03). This study was rated fair quality because more than 20 percent of the breastfeeding data were missing.

Anderson 2005 was an RCT with a total of 182 mother-infant pairs from a low income and largely Hispanic (70%) population. ^20^ The intervention was visits by two trained breastfeeding peer counselors. The women were offered three prenatal home visits, daily in-hospital visits during postpartum hospitalization, and nine postpartum home visits. The study found that the exclusive breastfeeding rate at 3 months in the intervention group was 20.6 percent versus 1.4 percent in the control group (P=0.008). The study reported that mothers in the intervention group was less likely to have menses return at 3 months compared with control (47.6% vs. 66.7%, P=0.031). For the infants, the risk of one or more diarrheal episode during the study was lower in the intervention group compared with control (17.5% vs. 37.5%, P=0.015). This study was rated fair quality because the allocation assignment was not properly concealed and it was unclear if the outcome assessors were blinded.

Pugh 2001 was a pilot “quasi-experimental” study with a total of 20 mother-infant pairs from low income, minority (40%) families. ^48^ The intervention was home visits by a breastfeeding support team consisting of a community health nurse and peer counselor. This team provided breastfeeding education and social support. It also provided instructions to decrease breast discomfort and fatigue. The intervention included a nurse visit during hospitalization and at least three home visits during weeks one, two, and four. In addition, peer counselors provided home visits and telephone support twice a week for the first 2 months, then weekly through the fifth month. The study found that 30 percent more women in the intervention group were breastfeeding at the fifth month compared with the control group. The study also found that the women in the intervention group had less fatigue at the fourth month (P=0.02) and less depressive and anxiety symptoms at the fifth month compared to control (P=NS). This study was rated poor quality because the details concerning the quasi-experimental design were not described.

### 2. What are the effects of a) prenatal, b) peripartum, and c) postpartum breastfeeding interventions on breastfeeding initiation, duration, and exclusivity?

A total of 25 RCTs in 26 publications ^20^ – ^45^ and four non-randomized controlled trials (non-RCTs) in five publications ^46^ – ^49,^ ^63^ examined the effect of breastfeeding interventions on breastfeeding initiation, duration, and/or exclusivity. Twenty-seven trials were conducted in developed countries. Two trials on BFHI were conducted in developing countries. The interventions included BFHI, breastfeeding education, professional supports (e.g., lactation consultants, midwives, nurses, physicians, and other health professionals), lay supports (e.g., peer support or counseling), delayed/discourage pacifier use, and skin-to-skin care. Nine trials (31%) were of good quality, eight trials (28%) were of fair quality, and 12 trials (41%) were of poor quality. Table 1 summarized the study characteristics.

Table 1 Characteristics of studies categorized according to methodological quality and first author

Study, year Country | Design | Intervention components | Control | Population Characteristics | Timing, Duration of intervention | Follow-up Duration | Applicability | Quality
Coutinho 2005 Brazil | RCT | Postnatal home visits by professionals + BFHI (step 4–9) | BFHI (step 4–9) | Low income; 24 hr hospital stay | Peri- & Postpartum, 10 visits | 6 mo | N | Good
Howard 2005 US | RCT | Delayed pacifier use (>4 wk) | Early pacifier use (days 2–5) | - | Postpartum, in hospital | 1 yr | W | Good
Kramer 2001 Canada | RCT | Discourage pacifier use + Professional support | Pacifier to sooth the infant +Professional support | - | Postpartum, in hospital | 3 mo | W | Good
Kramer 2001 Belarus | Cluster RCT | BFHI (Modeled) | Standard care | Prolonged postpartum stay; maternity leave | Peri- & Postpartum, 18-hr course; 12 to 16 mo implement | 1 yr | N | Good
Lavender 2005 UK | Cluster RCT | Education session to midwives | Usual prenatal BF advice | - | Prenatal, single session 1 day | 1 yr | N | Good
Labarere 2003 France | RCT | Education | Usual care in hospital | Prolonged maternity leave | Postpartum, 30 min | 17 wk | N | Good
Labarere 2005 France | RCT | Training primary care physicians^a^ | Usual care, including peer support | Prolonged hospital stay | Postpartum, 1 outpatient visit within 2 wk | 1 mo | N | Good
Noel-Weiss 2006 Canada | RCT | Education | Not described (no Education workshop) | Family income > $70,000 | Prenatal, 2.5 hr | 2 mo | N | Good
Wallace 2006 UK | RCT | Education workshop to midwives^b^ | Usual postpartum care | - | Postpartum, 4 hr | 17 wk | W | Good
Anderson 2005 US | RCT | Lay support + BFHI | BFHI | Latina, low-income, WIC | Prenatal & Postpartum, prenatal home visits (2.6 hr) and in-hospital visits (2.2 hr) | 3 mo | W | Fair
Bonuck 2005;2006 US | RCT | Professional support, Education, provide nursing bras & pump | Usual prenatal care | 56% Medicaid | Prenatal & Postpartum, 2 prenatal meetings (60 min each), a postpartum hospital, and/or home visits (90 min) and telephone support | 1 yr | W | Fair
Carfoot 2005 UK | RCT | Skin-to-skin | Routine care | - | Postpartum, n/a | 4 mo | N | Fair
Forster 2004 Australia | RCT | Education (Practical Skills) | Standard care^c^ | - | Prenatal, 1.5 hr | 6 mo | N | Fair
Education (Attitude) | Prenatal, 2 hr
Henderson 2001 Australia | RCT | Education | Usual postpartum care | - | Postpartum, 30 min | 6 mo | N | Fair
Mizuno 2004 Japan | RCT | Skin-to-skin | Routine care | - | Postpartum, n/a | 1 yr | N | Fair
Muirhead 2006 Scotland | RCT | Lay support | Usual support from midwife | Some premature babies (5.3%) and babies in special care (6.3%) | Prenatal & Postpartum, >1 prenatal visit, >every 2 d after returning home until day 28 | 4 mo | N | Fair
Pisacane 2005 Italy | Non-RCT^k^ | Education + Leaflet | Childcare education + Leaflet | Married parents only | Prenatal, a 40-min session | 1 yr | N | Fair
Carfoot 2004^j^ UK | RCT | Skin-to-skin | Routine care | - | Postpartum, n/a | 4 mo | N | Poor
Chertok 2006;2004 Israel | Non-RCT^d^ | Professional support, Education, Early SSC | Routine care | Muslim or Jewish | Postpartum, 1 time Education & Professional support | 4 mo | N | Poor
Ekstrom 2006 Sweden | Quasi-RCT | Training health professionalse | Standard care, including prenatal family classes | 97% BF initiation rate in the control group | Prenatal, 7 sessions of training for health professionals | 9 mo | N | Poor
Finch 2002 US | RCT | Education + Incentives | Usual prenatal Education | Low income; WIC | Prenatal, nd | 2 mo | W | Poor
McKeever 2002 Canada | RCT | Professional support | No home visits | - | Postpartum, maximum of 3 home visits | 5 to 12 days | W | Poor
McLeod 2004 New Zealand | Quasi-RCT | Professional support, Education (BF support only) | Usual care for women who smoked^f^ | Mori; Smokers | Prenatal & Postpartum, nd | 4 mo | N | Poor
Professional support, Education (BF support & smoking cessation) | Prenatal & Postpartum, nd
Pugh 2001 US | “Quasi experimental” | Lay support, Education, Professional support | Usual postpartum care | Low-income, mostly single women | Postpartum, 1 hospital visit; >3 home visits & telephone support | 5 mo | W | Poor
Reeve 2004 UK | Non-RCT^g^ | Education | Routine prenatal care | - | Prenatal, 2 hr | 4 mo | N | Poor
Ryser 2004 US | RCT | Education (Best Start Program) | No intervention | Low income | Prenatal, 4 visits | 1 wk | N | Poor
Schlickau 2005 US | RCT | Education | Usual care^h^ | Hispanic women, emigrated from Mexico | Prenatal, 1 hr | 45 d | N | Poor
Education + commitment-to-breastfeed | Prenatal, 2 hr
Wilhelm 2006 US | RCT | Motivational interview | Usual care | Rural community | Postpartum, nd | 6 mo | N | Poor
Wolfberg 2004 US | RCT | Education (taught by peer) | Control Education (baby care and safety) | Low-income, minority | Prenatal, 2 times; 2 hr eachi | 2 mo | N | Poor

FT, full term; n/a, not applicable; WIC, Women, Infants, and Children program; N, narrow; W, wide

a Pediatricians or family physicians, who had attended a 5-hour training program (breastfeeding-related knowledge and counseling skills) delivered in 2 parts in 1 month before the beginning of the study

b Midwives who received a 4-h workshop (hands off" approach to BF: advice about baby initiation of feeding, positioning and attachment)

c Including formal breastfeeding education, peer support and postnatal home visits by midwives; the same control group was used to compare both intervention groups (Practical Skills or Attitudes)

d Control group subjects were recruited between December 2000 through July 2001, while intervention group subjects were recruited from December 2001 to July 2002

e Health professionals received a process-oriented program on breastfeeding counseling, including lectures on breastfeeding management and promotion, counseling skills and personal breastfeeding experiences

f The same control group was used to compare both intervention groups (BF support only or BF support & smoking cessation)

g Non-random block allocation

h The same control group was used to compare both intervention groups (Education or Education + commitment-to-breastfeed)

i Two classes, 2-hour for each class and 2 weeks apart

j Pilot study of Carfoot 2005

k The fathers of the newborn were allocated to the study groups according to the date of birth of their infants in 2 time blocks: October to November 2002 (intervention group), and December 2002 and January 2003 (control group). This study was not included in the meta-analyses because it was identified after the submission of the final report.

A recent Cochrane systematic review identified eight RCTs published after 2001 conducted in developed countries. ^13^ We elected to include data from these studies in our meta-analyses. However, we did not grade the quality or applicability of these RCTs. The quality was assumed to be of good or fair in our meta-analyses because only trials with a minimum of 75% followup were included in the Cochrane review.

## Meta-analyses of Breastfeeding Interventions on Rate of Breastfeeding Initiations, Durations, Compared to Usual Care

Studies comparing the effects of primary care initiated breastfeeding interventions to usual care are heterogeneous in many respects: different combinations of intervention components and background social support, different health care systems defining “usual” or “routine” care, different timing and intensities of the interventions, and diverse study populations.(Table 2) We did not find statistical heterogeneity among trials in three categories of breastfeeding (any intermediate, exclusive intermediate, and prolonged). There was significant statistical heterogeneity among trials in the remaining breastfeeding categories (P<0.02). Comparing the intervention to the control, our meta-analyses consistently showed an increased rate of any or exclusive breastfeeding initiation, short-, intermediate, and long-term breastfeeding, although most of these findings were not statistically significant. (Figures 3 and 4)

Table 2 Meta-analyses by exclusivity of breastfeeding

Breastfeeding Duration | Any | | | Exclusive | | | P any vs. exclusive*
# Study | Pooled RR (95% CI) | I^2^ | # Study | Pooled RR (95% CI) | I^2^
Initiation | 15 | 1.07 (1.01, 1.14) | 89% | 9 | 1.05 (0.97, 1.14) | 57% | 0.32
Short | 19 | 1.09 (1.01, 1.18) | 67% | 11 | 1.85 (0.90, 3.83) | 99% | 0.07
Intermediate | 13 | 1.08 (0.98, 1.19) | 25% | 5 | 1.47 (0.95, 2.29) | 31% | 0.09
Long | 10 | 1.12 (0.94, 1.35) | 85% | 6 | 2.27 (0.66, 7.84) | 96% | 0.14
Prolonged | 3 | 1.06 (0.75, 1.48) | 19% | - | -

* Z test

Figure 3. Meta-analyses of the effect of primary care initiated breastfeeding interventions comparing to usual care on any breastfeeding initiation and durations

Figure 4. Meta-analyses of the effect of primary care initiated breastfeeding interventions comparing to usual care on exclusive breastfeeding initiations and durations

### The Impacts of Any versus Exclusive Breastfeeding (Table 2)

Comparing breastfeeding interventions to the control, the pooled rate ratios of exclusive short-term and intermediate breastfeeding were larger than that of any short-term, and intermediate breastfeeding, respectively (P<0.10). Although not statistically significant, the pooled rate ratio of exclusive long-term breastfeeding was twice as large as that of any long-term breastfeeding.

### The Impacts of Study Quality (Table 3)

We performed subgroup analyses by study quality (good or fair versus poor) on the pooled rate ratios of any or exclusive breastfeeding initiation, short-, intermediate, and long-term breastfeeding. Overall, the impacts of study quality on the pooled rate ratios of breastfeeding initiation and durations were inconsistent. Comparing breastfeeding interventions to the control, the pooled rate ratios of any breastfeeding initiation and exclusive intermediate breastfeeding were larger in poor quality studies than the pooled rate ratios in good/fair quality studies (P=0.09 in the former and 0.02 in the latter). There were no other significant or borderline significant differences found.

Table 3 Meta-analyses by quality of studies

Breastfeeding | Good/Fair Quality | | | | Poor Quality | | | P good/fair vs. poor**
Duration | # Study | Pooled RR (95% CI) | I^2^ | # Study | Pooled RR (95% CI) | I^2^
Any | Initiation | 7 | 1.04 (0.98, 1.10) | 88% | 8 | 1.14 (1.00, 1.31) | 88% | 0.09
Any | Short | 14 | 1.07 (0.96, 1.19) | 74% | 5 | 1.07 (0.86, 1.32) | 0% | 0.50
Any | Intermediate | 6 | 1.09 (0.95, 1.24) | 23% | 7 | 1.09 (0.91, 1.29) | 36% | 0.50
Any | Long | 8 | 1.15 (0.94, 1.40) | 86% | 2 | 0.96 (0.79, 1.18) | 0% | 0.11
Prolonged | 2 | 1.34 (0.75, 2.41) | 10% | 1 | 0.91 (0.65, 1.28)* | -
Exclusive | Initiation | 6 | 1.01 (0.96, 1.06) | 0% | 3 | 2.20 (0.56, 8.56) | 92% | 0.13
Exclusive | Short | 11 | 1.85 (0.90, 3.83) | 99% | - | - | - | -
Exclusive | Intermediate | 3 | 1.03 (0.58, 1.77) | 0% | 2 | 2.00 (1.41, 2.84) | 92% | 0.02
Exclusive | Long | 6 | 2.27 (0.66, 7.84) | 96% | - | - | | -
Prolonged | - | - | - | - | - | | -

* Result of single study

** Z test

### The Impacts of Timing of Breastfeeding Interventions (Table 4)

We performed subgroup analyses by timing of breastfeeding interventions (prenatal, postpartum, or combined prenatal and postpartum) on the pooled rate ratios of any or exclusive breastfeeding initiation, short-, intermediate, and long-term breastfeeding. There were 18, 19, and 23 trials that examined the effects of prenatal, combination of pre- and postnatal, and postnatal breastfeeding interventions, respectively, on any breastfeeding initiation and durations. The results suggest that prenatal breastfeeding interventions significantly increased the rate of any short-term breastfeeding compared to usual care (pooled RR: 1.39; 95%CI 1.16–1.67), while other timing of breastfeeding interventions did not change the outcome significantly. In addition, combination of pre- and postnatal breastfeeding interventions significantly increased both the rates of intermediate and long-term any breastfeeding compared to usual care (pooled RR: 1.15; 95%CI 1.00–1.32, 1.38; 95%CI 1.33–1.43, respectively), while other timing of breastfeeding interventions did not change the outcomes significantly. In interventions that had combined pre- and postnatal components, results from meta-regression suggest that larger effects (compared to control) were associated with longer breastfeeding durations (P<0.001). This association was not found in solely pre- or postnatal interventions.

Table 4 Subgroup analyses by timing of intervention

Timing of Intervention | Breastfeeding | Breastfeeding Duration | # Study | Pooled RR (95% CI) | P for trend**
Prenatal alone | Any | Initiation | 7 | 1.04 (0.99, 1.09) | 0.27
Prenatal alone | Any | Short | 5 | 1.39 (1.16, 1.67) | 0.27
Prenatal alone | Any | Intermediate | 2 | 1.44 (0.60, 3.47) | 0.27
Prenatal alone | Any | Long | 3 | 0.96 (0.87, 1.06) | 0.27
Prolonged | Any | 1 | 0.91 (0.65, 1.28)*
Pre- and postnatal | Any | Initiation | 4 | 1.10 (0.91, 1.33) | <0.001
Pre- and postnatal | Any | Short | 7 | 1.03 (0.85, 1.26) | <0.001
Pre- and postnatal | Any | Intermediate | 5 | 1.15 (1.00, 1.32) | <0.001
Pre- and postnatal | Any | Long | 2 | 1.38 (1.33, 1.43) | <0.001
Prolonged | Any | 1 | 1.19 (0.72, 1.97)*
Postnatal alone | Any | Initiation | 4 | 1.13 (0.91, 1.39) | 0.33
Postnatal alone | Any | Short | 7 | 1.05 (0.95, 1.15) | 0.33
Postnatal alone | Any | Intermediate | 6 | 1.06 (0.95, 1.17) | 0.33
Postnatal alone | Any | Long | 5 | 1.23 (0.89, 1.68) | 0.33
Prolonged | 1 | 2.80 (0.62, 12.7)*
Prenatal alone | Exclusive | Initiation | 4 | 1.09 (0.90, 1.33) | 0.35
Prenatal alone | Exclusive | Short | 1 | 1.41 (1.08, 1.84)* | 0.35
Prenatal alone | Exclusive | Intermediate | - | - | 0.35
Prenatal alone | Exclusive | Long | 2 | 1.17 (0.80, 1.73) | 0.35
Prolonged | Exclusive | - | -
Pre- and postnatal | Exclusive | Initiation | 2 | 1.15 (0.83, 1.58) | 0.23
Pre- and postnatal | Exclusive | Short | 6 | 2.52 (0.85, 7.47) | 0.23
Pre- and postnatal | Exclusive | Intermediate | 1 | 5.00 (0.24, 103) | 0.23
Pre- and postnatal | Exclusive | Long | 3 | 3.75 (0.66, 21) | 0.23
Prolonged | Exclusive | - | -
Postnatal alone | Exclusive | Initiation | 3 | 1.05 (0.96, 1.13) | <0.001
Postnatal alone | Exclusive | Short | 4 | 1.21 (1.08, 1.36) | <0.001
Postnatal alone | Exclusive | Intermediate | 4 | 1.41 (0.88, 2.27) | <0.001
Postnatal alone | Exclusive | Long | 1 | 1.90 (0.55, 6.60) | <0.001
Prolonged | - | -

* Result from single study

** Random-effect meta-regression based on individual studies

There were seven, 12, and 12 trials that examined the effects of prenatal, combination of pre- and postnatal, and postnatal breastfeeding interventions, respectively, on exclusive breastfeeding initiation and durations. No significant differences in the outcomes were found between the timing of breastfeeding interventions, except that postnatal breastfeeding interventions significantly increased the rate of exclusive short-term breastfeeding compared to usual care (pooled RR: 1.21; 95%CI 1.08–1.36). In interventions that had only postnatal components, results from meta-regression suggest that larger effects (compared to control) were associated with longer exclusive breastfeeding durations (P<0.001). This association was not found for prenatal alone or combined pre- and postnatal breastfeeding interventions.

## Subgroup Analyses of Different Interventions

We performed subgroup analyses to examine the effects of different components of breastfeeding interventions on breastfeeding initiation, duration, and exclusivity. The interventions of interest have been classified into the following categories for the analyses: formal/structured breastfeeding education, professional support (system or individual level support), lay support, other breastfeeding interventions, and Baby Friendly Hospital Initiative (BFHI). The components of breastfeeding interventions are not mutually exclusive. In other words, if a trial had multiple components, this trial would appear in different subgroup analyses. BFHI is also considered one form of professional support. The detailed classification of the interventions is described in Table 1.

### Formal/Structured Breastfeeding Education (Table 5)

Formal/structured breastfeeding education with or without other components significantly increased the rate of any breastfeeding initiation compared to usual care (pooled RR: 1.15; 95%CI 1.02–1.30). However, there were no significant differences in the rate of exclusive breastfeeding initiation or durations between the breastfeeding education and usual care group.

Table 5 Meta-analyses of breastfeeding education versus usual care

Intervention | Breastfeeding | Breastfeeding Duration | # Study | Pooled RR (95% CI) | P for trend
Education with or without other components | Any | Initiation | 9 | 1.15 (1.02, 1.30) | 0.45
Education with or without other components | Any | Short | 7 | 1.11 (0.92, 1.33) | 0.45
Education with or without other components | Any | Intermediate | 7 | 1.14 (0.93, 1.41) | 0.45
Education with or without other components | Any | Long | 3 | 0.95 (0.86, 1.05) | 0.45
Prolonged | 1 | 1.19 (0.72, 1.97)
Education with or without other components | Exclusive | Initiation | 4 | 1.09 (0.90, 1.33) | 0.15
Education with or without other components | Exclusive | Short | 2 | 1.17 (0.67, 2.05) | 0.15
Education with or without other components | Exclusive | Intermediate | 2 | 1.52 (0.71, 3.24) | 0.15
Education with or without other components | Exclusive | Long | 3 | 1.05 (0.74, 1.50) | 0.15
Prolonged | - | -

* Result from single study

** Random-effect meta-regression on individual studies

### Professional Support (Table 6)

Professional support can be further broken down into two sub-categories: system level and individual level professional support. System level professional support includes training of health professional to increase breastfeeding promotion knowledge and skills, and BFHI. Individual level professional support includes all forms of one-to-one breastfeeding support or promotion during hospital stay or outpatient visits or social support after discharge (e.g., home visits or telephone support) from health professionals.

Table 6 Meta-analyses of professional support versus usual care

Breastfeeding | System-level support | | | | Individual-level support with or without other components
Duration | # Study | Pooled RR (95% CI) | P for trend** | # Study | Pooled RR (95% CI) | P for trend**
Any | Initiation | 2 | 1.06 (0.95, 1.17) | 0.92 | 6 | 1.15 (0.84, 1.57) | 0.59
Any | Short | 3 | 0.96 (0.73, 1.26) | 0.92 | 7 | 1.00 (0.92, 1.09) | 0.59
Any | Intermediate | 2 | 0.97 (0.84, 1.11) | 0.92 | 6 | 1.12 (1.01, 1.25) | 0.59
Any | Long | 2 | 1.16 (0.80, 1.68) | 0.92 | 2 | 1.31 (0.95, 1.84) | 0.59
Prolonged | 1 | 0.91 (0.65, 1.68)* | 1 | 1.19 (0.72, 1.97)*
Exclusive | Initiation | - | - | - | 3 | 1.04 (0.97, 1.12) | 0.23
Exclusive | Short | 3 | 1.89 (0.41, 8.80) | - | 3 | 1.90 (0.63, 5.70) | 0.23
Exclusive | Intermediate | 1 | 0.97 (0.35, 2.69)* | - | 1 | 2.12 (1.46, 3.07)* | 0.23
Exclusive | Long | 1 | 13.3 (9.9, 17.8)* | - | 3 | 1.91 (0.42, 8.62) | 0.23
Prolonged | - | -

* Result from single study

** Random-effect meta-regression on individual studies

We identified five trials comparing system level professional support to usual care. The data on the effect of system level professional support compared to usual care were sparse: only less than three trials for each breastfeeding category. Our meta-analyses found no significant effect of system level professional support on breastfeeding initiation or duration compared to usual care. However, one study reported that BFHI significantly increased both short- and long-term exclusive breastfeeding. ^41^

Individual level professional support with or without other components significantly increased the rate of any intermediate breastfeeding compared to usual care (pooled RR: 1.12; 95%CI 1.02–1.30). Our meta-analyses found no significant effect of individual level professional support on breastfeeding initiation or duration compared to usual care. However, one study reported that postnatal home visits by health professionals in addition to usual care (BFHI) significantly increased both short- and long-term exclusive breastfeeding. ^25^

### Lay Support (Table 7)

Lay support with or without other components significantly increased the rate of any short- and long-term breastfeeding compared to usual care (pooled RR: 1.26; 95%CI 1.07–1.48, 1.38; 95%CI 1.00–1.92, respectively). Results from meta-regression suggest that larger effects (compared to control) were associated with longer exclusive breastfeeding durations (P=0.008).

Table 7 Meta-analyses of lay support versus usual care

Intervention | Breastfeeding | Breastfeeding Duration | # Study | Pooled RR (95% CI) | P for trend**
Lay support with or without other components | Any | Initiation | 1 | 1.07 (0.94, 1.21)* | 0.008
Lay support with or without other components | Any | Short | 5 | 1.26 (1.07, 1.48) | 0.008
Lay support with or without other components | Any | Intermediate | 2 | 1.48 (0.73, 3.00) | 0.008
Lay support with or without other components | Any | Long | 2 | 1.38 (1.00, 1.92) | 0.008
Prolonged | - | -
Lay support with or without other components | Exclusive | Initiation | 1 | 1.39 (1.01, 1.92)* | 0.83
Lay support with or without other components | Exclusive | Short | 4 | 1.66 (1.05, 2.63) | 0.83
Lay support with or without other components | Exclusive | Intermediate | 1 | 5.00 (0.24, 102)* | 0.83
Lay support with or without other components | Exclusive | Long | 1 | 1.90 (0.55, 6.60)* | 0.83
Prolonged | - | -

* Result from single study

** Random-effect meta-regression on individual studies

Two of the five trials on the effects of lay support with or without other components were conducted in BFHI hospitals. ^20,^ ^61^ The pooled rate ratio of any short-term breastfeeding from these two trials was 1.43 (95%CI 1.07, 1.92).

For outcomes of exclusive breastfeeding initiation and durations, meta-analysis was only performed for the effect of short-term exclusive breastfeeding. The result showed that lay support with or without other components significantly increased short-term exclusive breastfeeding duration (pooled RR: 1.66; 95%CI 1.05–2.56), compared to usual care.

### Baby Friendly Hospital Initiative (Table 8; Appendix J)

We identified two good quality RCTs, ^25,^ ^41^ two poor quality experimental studies, ^50,^ ^51^ and four poor quality observational studies. ^52^ – ^55^ The two good quality studies were the PROBIT study as detailed previously, and a trial in Brazil on a population with high poverty and infant mortality rates. ^25^ The PROBIT study compared an intervention based on BFHI with standard care, while the study in Brazil compared BFHI with home visits by health professionals to BFHI without home visits. Both studies found an increased exclusive breastfeeding rates at 3 and 6 months comparing intervention with control (Table 8). The PROBIT study also reported an increased ever breastfeeding rate at 12 months. The study from Brazil did not have 12 months data.

Table 8 RCTs of Baby Friendly Hospital Initiative (BFHI)

Study Year Country | Population | Intervention (N) vs. Control (N) | Outcome | | | | Applic | Quality
Initiation | Exclu BF at 3 mo | Exclu BF at 6 mo | Others
Kramer 2001 (Cluster RCT) Belarus | Urban and rural, >95% completed secondary education | Modeled BFHI (8847) vs. no BFHI (7895) | 100% vs. 100% | 43.3% vs. 6.4% (P <0.001) | 7.9% vs. 0.6% (P=0.01) | Ever BF at 12 mo 19.7% vs. 11.4% | Narrow | Good
Coutinho 2005 Brazil | Urban, widespread poverty, 33% illiteracy rate | BFHI with postnatal home visits (175) vs. BFHI (175) only | 70% vs. 70% | 45% (est.) vs. 10% (est.) | 25% (est.) vs. 4% (est.) | Aggregate exclu BF rate days (10–180) 45% vs. 13% (P<0.0001) | Narrow | Good

The two experimental studies were non-randomized before-after BFHI training design conducted in Italy ^50^ and Taiwan, ^51^ respectively. The study in Italy found a significant increase in exclusive breastfeeding rate at discharge, full breastfeeding rate at 3 months, and ever breastfeeding rate at 6 months, comparing intervention to control. The study in Taiwan found a significant increase in the exclusive breastfeeding rates at discharge, 2 weeks, 1 and 2 months postpartum, comparing intervention with control. Both studies were rated poor because of the study design.(Appendix J)

The other four observational studies were cohort studies comparing mother-infant pairs from hospitals with high breastfeeding promotion to mother-infant pairs from low breastfeeding promotion (assessed either by the number of steps fulfilling BFHI or a breastfeeding promotion index analogous to BFHI). (Appendix J) The study from the Czech Republic found that the durations of exclusive breastfeeding were comparable in both groups (3.9 months ± 1.92 SD in BFHI vs. 3.9 months ± 1.92 SD in others). ^52^ This study was rated poor because of the study design and the apparent lack of control for characteristics differences between groups. The study from Croatia reported an increase in general breastfeeding rates at 3 (66% vs. 30%, P<0.05), 6 (49% vs. 11%, P<0.05), 9 (35% vs. 6%, P<0.05), and 12 months (23% vs. 2%, P<0.05), comparing BFHI with postnatal support (1999-2000) to a historical cohort (1990-1993) without BFHI. ^55^ This study was rated poor because of the study design and large loss (57%) to followup. The study from Germany found an increased risk of short-term breastfeeding (<4 months full breastfeeding) in mother-infant pairs discharged from a hospital with low breastfeeding promotion index (adjusted OR: 1.24; 95%CI 0.99–1.55) compared to a hospital with high breastfeeding promotion index. ^53^ This study was rated poor because of the study design and low enrollment rate (45%). The study from Scotland found an increased odds ratio of breastfeeding at 1 week (adjusted OR 1.28, 95%CI 1.24–1.31) if an infant was born in a UK hospital with the BFHI standard award compared to an infant born in a hospital without BFHI accreditation. ^54^ This study was rated poor because of the study design and no details concerning breastfeeding were provided.

## Differences in Absolute Breastfeeding Durations (Table 9)

Eight trials in nine publications reported the differences in the absolute breastfeeding duration comparing the breastfeeding intervention to usual care groups. ^27,^ ^29,^ ^32,^ ^34,^ ^37,^ ^39,^ ^43,^ ^44,^ ^62^ Three were good, two were fair, and three were poor quality. The followup durations ranged from 45 days to 1 year. We did not perform meta-analyses because the intervention components and outcome matrix varied greatly across these trials.

Table 9 The effects of primary care initiated breastfeeding interventions on absolute breastfeeding durations compared to usual care

Study, year Country | Intervention components | Outcome Definition | Dur of f/up | Units | Group | N | Final | SD | Diff | 95%CI or P_b/tw_ | Quality
Howard 2005 US | Delayed pacifier use (>4 wk) | Exclusive BF duration | 1 yr | day | BF promotion | 346 | 28^a^ | | Adjusted HR: 1.09 | 0.94–1.27 | Good
Control | 354 | 21
Howard 2005 US | Delayed pacifier use (>4 wk) | Full BF duration | 1 yr | day | BF promotion | 346 | 52^a^ | | Adjusted HR: 1.04 | 0.89–1.21 | Good
Control | 354 | 49^a^
Howard 2005 US | Delayed pacifier use (>4 wk) | Ever BF duration | 1 yr | day | BF promotion | 346 | 163^a^ | | Adjusted HR: 1.22 | 1.03–1.44 | Good
Control | 354 | 140^a^
Labarere 2005 France | Training primary care physicians^e^ | Any BF duration | 2 mo | Week | BF promotion | 112 | 18^a^ | | HR: 1.40 | 1.03–1.92 | Good
Control | 114 | 13^a^
Noel-Weiss 2006 Canada | Education | BF duration | 2 mo | day | BF promotion | 41 | 54 | 9.3 | | NS | Good
Control | 51 | 47 | 17
Forster 2004 Australia | Education (Practical Skills) | Any BF duration | 6 mo | Week | BF promotion | 297 | 19 | 9.3 | 1 | NS | Fair
Control | 299 | 18 | 9.7
Forster 2004 Australia | Education (Attitudes) | Any BF duration | 6 mo | Week | BF promotion | 293 | 17 | 10 | -1 | NS | Fair
Control | 299 | 18 | 9.7
Mizuno 2004 Japan | Skin-to-skin | nd | 1 yr | Month | BF promotion | 30 | 6.7 | 3.7 | 1.9 | 0.016 | Fair
Control | 28 | 4.8 | 2.5
Schlickau 2005 US | Education^d^ | BF duration | 45 d | day | BF promotion | 9 | 23 | 16 | 6.3 | NS | Poor
Control | 7 | 16 | 18
Schlickau 2005 US | Education + commitment-to-breastfeed^d^ | BF duration | 45 d | day | BF promotion | 9 | 31 | 16 | 14.3 | NS | Poor
Control | 7 | 17 | 18
Ekstrom 2006 Sweden | Professional support | Exclusive BF duration^b^ | 9 mo | Month | BF promotion | nd | 3.9 | 2.2 | | NS | Poor
Control | nd | 3.5 | 2.0
Ekstrom 2006 Sweden | Professional support | Exclusive & partial BF duration | 9 mo | Month | BF promotion | nd | 7.5 | 4.7 | | NS | Poor
Control | nd | 7.0 | 4.5
Wilhelm 2006 US | Motivational interview | BF duration | 6 mo | day | BF promotion | 36 | 98 | 75 | Adjusted mean difference^c^ = 12 | NS | Poor
Control | 35 | 81 | 72

P b/tw, p valued for the differences between the comparison groups; d, day(s); wk, week(s); mo, month(s); yr, year(s)

a Median

b including some babies received supplementary feeding with formula during the first week of life

c Adjusted for baseline breastfeeding self-efficacy and length of time before returning to work

d The same control group was used to compare both intervention groups (Education or Education + commitment-to-breastfeed)

e Pediatricians or family physicians, who had attended a 5-hour training program (breastfeeding-related knowledge and counseling skills) delivered in 2 parts in 1 month before the beginning of the study

One good quality trial comparing delayed pacifier use to pacifier use within 2 to 5 days found an increase in any breastfeeding duration (adjusted HR 1.22, 95%CI 1.03–1.44). ^29^ Another good quality trial comparing system-level professional support to usual care also found a significant increase in any breastfeeding duration (adjusted HR: 1.40, 95%CI 1.03–1.92). ^32^ One fair quality trial showed that postpartum skin-to-skin care resulted in about a 2-months increase in breastfeeding duration, compared to usual care, at the end of 1-year followup. ^34^ There were no other trials that showed a significant difference in absolute breastfeeding durations between the intervention and the control groups.

## Interventions Involving Family Members

We identified only two studies involving family members in breastfeeding intervention, a RCT (poor quality) in United States and non-randomized but controlled trial (fair quality) in Italy of breastfeeding education involving expectant fathers. ^40,^ ^63^

Pisacane 2005 compared the effects of a face-to-face, 40-minute education session concerning the management of breastfeeding difficulties for expectant fathers to a control group that received education session on childcare on the rates of full or any breastfeeding initiation, as well as, full or any breastfeeding at 6 and 12 months. ^63^ The fathers of the newborns were allocated to the study groups according to the date of birth of their infants: those whose infants were born in October and November 2002 were assigned to the intervention group, and those whose infants were born in December 2002 and January 2003 were assigned the control group. A trained midwife conducted the breastfeeding education session. Another researcher conducted the control education session. The results showed no significant differences in the rates of full or any breastfeeding initiation. However, significantly more women whose husbands attended the breastfeeding education session were still fully breastfeeding at 6 months, compared to women whose husbands attended the control education session (25% vs. 15%, P<0.05). Any breastfeeding rate was also higher, but not statistically significant, in those women whose husbands attended the breastfeeding education session at 12 months (19% vs. 11%, P=0.09). This study was graded fair because no apparent adjustment was made to account for the fact that the two interventions took place during two different time periods.

Wolfberg 2004 compared the effects of breastfeeding classes for expectant fathers to control classes of baby care and safety on rates of any breastfeeding initiation and any breastfeeding at 2 months. ^40^ A peer classroom facilitator who was easygoing and engaging, knowledgeable without being overbearing, African-American, and who was a father himself gave the expectant fathers two prenatal breastfeeding classes (2 hours for each class and 2 weeks apart). The study found that more women whose partners attended the breastfeeding classes initiated breastfeeding than women whose partners attended the control classes (74% vs. 41%, P=0.02). Other characteristics were also associated with an increased incidence of breastfeeding initiation in the study, including mother's plan to breastfeed for the first month (P=0.004), baby's maternal grandmother's belief that the baby should be breastfed (P=0.03), mother's belief that her partner thinks her baby should be breastfed (P=0.002), and father's belief that the baby should be breastfed (P=0.03) There was no significant difference in the rate of any breastfeeding at 2 months between the intervention and the control groups. This study was graded poor because of low enrollment rate and the method of randomization and the blinding of outcome assessors were unclear.

### 3. Are there harms from interventions to promote and support breastfeeding?

We did not identify any study from our search that was designed specifically to examine harms from interventions to promote and support breastfeeding.