# Appendix 3: Results including starting at age 40 in efficient and near-efficient frontiers

Table 1. Colonoscopy strategies

Table 2. Hemoccult II strategies

Table 3. Hemoccult SENSA strategies

Table 4. FIT strategies

Table 5. Flexible sigmoidoscopy strategies

Table 6. Flexible sigmoidoscopy + Hemoccult SENSA strategies

Table 1 Colonoscopy strategies

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
| | COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
1 | COL, 60–75, 20 | 2,175 | 156 | | | ---
2 | COL, 50–75, 20 | 3,325 | 203 | 1,150 | 47 | 24.7
3 | COL, 50–75, 10 | 4,136 | 230 | 811 | 27 | 29.6
4 | COL, 50–85, 10 | 4,534 | 236 | 398 | 5 | 72.9
5 | COL, 40–75, 10 | 5,231 | 242 | | | Near efficient
6 | COL, 40–85, 10 | 5,629 | 248 | | | Near efficient
7 | COL, 50–75, 5 | 5,895 | 254 | 1,362 | 18 | 74.8
8 | COL, 50–85, 5 | 6,460 | 257 | | | Near efficient
9 | COL, 40–75, 5 | 7,881 | 276 | 1,986 | 22 | 90.6
10 | COL, 40–85, 5 | 8,445 | 279 | 564 | 4 | 158.6
SimCRC
1 | COL, 60–75, 20 | 1,780 | 165 | | | ---
2 | COL, 40–75, 20 | 3,131 | 275 | 1,352 | 110 | 12.2
3 | COL, 40–75, 10 | 4,887 | 320 | 1,755 | 45 | 38.6
4 | COL, 40–85, 10 | 5,245 | 322 | | | Near efficient
5 | COL, 40–75, 5 | 7,578 | 331 | 2,691 | 11 | 245.1
6 | COL, 40–85, 5 | 8,036 | 332 | 459 | 1 | 875.4

COL = colonoscopy; LYG = life-years gained compared with no screening; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best non-efficient strategy.

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Table 2 Hemoccult II strategies

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
| | COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
1 | Hemoccult II, 60–75, 3 | 681 | 89 | | | ---
2 | Hemoccult II, 60–75, 2 | 854 | 105 | 172 | 16 | 10.6
3 | Hemoccult II, 50–75, 3 | 1,033 | 121 | | | Near-efficient
4 | Hemoccult II, 50–75, 2 | 1,335 | 149 | 482 | 44 | 11.0
5 | Hemoccult II, 50–85, 2 | 1,513 | 158 | | | Near-efficient
6 | Hemoccult II, 50–75, 1 | 1,982 | 194 | 647 | 45 | 14.3
7 | Hemoccult II, 50–85, 1 | 2,186 | 202 | 203 | 8 | 25.5
8 | Hemoccult II, 40–75, 1 | 2,649 | 219 | 464 | 17 | 27.7
9 | Hemoccult II, 40–85, 1 | 2,842 | 225 | 193 | 7 | 29.0
SimCRC
1 | Hemoccult II, 60–75,3 | 425 | 75 | | | ---
2 | Hemoccult II, 50–75,3 | 699 | 129 | 275 | 54 | 5.1
3 | Hemoccult II, 40–75,2 | 1,327 | 211 | 407 | 49 | 8.3
4 | Hemoccult II, 40–75,1 | 2,083 | 275 | 756 | 64 | 11.8
5 | Hemoccult II, 40–85,1 | 2,354 | 280 | 271 | 5 | 58.2

COL = colonoscopy; LYG = life-years gained compared with no screening; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best non-efficient strategy.

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Table 3 Hemoccult SENSA strategies

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
| | COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
1 | Hemoccult SENSA, 60–75, 3 | 1,363 | 134 | | | ---
2 | Hemoccult SENSA, 60–75, 2 | 1,647 | 149 | | | Near-efficient
3 | Hemoccult SENSA, 50–75, 3 | 2,121 | 181 | 758 | 47 | 16.0
4 | Hemoccult SENSA, 50–75, 2 | 2,584 | 205 | 463 | 24 | 19.5
5 | Hemoccult SENSA, 50–85, 2 | 2,801 | 211 | | | Near-efficient
6 | Hemoccult SENSA, 50–75, 1 | 3,350 | 230 | 766 | 25 | 30.9
7 | Hemoccult SENSA, 40–75, 2 | 3,503 | 230 | | | Near-efficient
8 | Hemoccult SENSA, 50–85, 1 | 3,538 | 232 | | | Near-efficient
9 | Hemoccult SENSA, 40–85, 2 | 3,695 | 234 | | | Near-efficient
10 | Hemoccult SENSA, 40–75, 1 | 4,416 | 251 | 1066 | 21 | 49.9
11 | Hemoccult SENSA, 40–85, 1 | 4,583 | 252 | 166 | 1 | 132.6
SimCRC
1 | Hemoccult SENSA, 60–75,3 | 934 | 123 | | | ---
2 | Hemoccult SENSA, 50–75,3 | 1,587 | 201 | 653 | 78 | 8.4
3 | Hemoccult SENSA, 40–75,3 | 2,304 | 256 | 717 | 55 | 13.0
4 | Hemoccult SENSA, 40–75,2 | 2,829 | 287 | 525 | 31 | 16.9
5 | Hemoccult SENSA, 40–85,2 | 3,167 | 291 | | | Near-efficient
6 | Hemoccult SENSA, 40–75,1 | 3,700 | 315 | 871 | 28 | 30.9
7 | Hemoccult SENSA, 40–85,1 | 4,039 | 317 | 339 | 2 | 149.8

COL = colonoscopy; LYG = life-years gained compared with no screening; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best non-efficient strategy.

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Table 4 FIT strategies

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
| | COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
1 | FIT, 60–75, 3 | 1,158 | 129 | | | ---
2 | FIT, 60–75, 2 | 1,403 | 144 | | | Near-efficient
3 | FIT, 50–75, 3 | 1,769 | 173 | 611 | 44 | 14.0
4 | FIT, 50–75, 2 | 2,184 | 198 | 415 | 25 | 16.5
5 | FIT, 50–85, 2 | 2,396 | 206 | | | Near-efficient
6 | FIT, 50–75, 1 | 2,949 | 227 | 765 | 30 | 25.9
7 | FIT, 40–85, 2 | 3,141 | 228 | | | Near-efficient
8 | FIT, 50–85, 1 | 3,155 | 231 | | | Near-efficient
9 | FIT, 40–75, 1 | 3,921 | 249 | 972 | 22 | 44.3
10 | FIT, 40–85, 1 | 4,104 | 252 | 184 | 3 | 70.2
SimCRC
1 | FIT, 60–75,3 | 772 | 118 | | | ---
2 | FIT, 50–75,3 | 1,286 | 193 | 514 | 75 | 6.9
3 | FIT, 40–75,3 | 1,846 | 244 | 560 | 51 | 10.9
4 | FIT, 40–75,2 | 2,330 | 279 | 484 | 35 | 14.0
5 | FIT, 40–85,2 | 2,636 | 283 | | | Near-efficient
6 | FIT, 40–75,1 | 3,236 | 313 | 906 | 34 | 26.4
7 | FIT, 40–85,1 | 3,568 | 316 | 333 | 3 | 118.7

COL = colonoscopy; LYG = life-years gained compared with no screening; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best non-efficient strategy.

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Table 5 Flexible sigmoidoscopy strategies

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
| | COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
1 | FSIG, 60–75, 20 | 1,047 | 114 | | | ---
2 | FSIG, 60–75, 10 | 1,311 | 140 | | | Near-efficient
3 | FSIG, 60–75, 5 | 1,491 | 159 | | | Near-efficient
4 | FSIG, 50–75, 10 | 1,685 | 177 | | | Near-efficient
5 | FSIG, 50–75, 5 | 1,911 | 203 | 864 | 89 | 9.7
6 | FSIG, 50–85, 5 | 1,996 | 207 | | | Near-efficient
7 | FSIG, 40–75, 5 | 2,122 | 219 | 211 | 16 | 13.4
8 | FSIG, 40–85, 5 | 2,206 | 222 | 84 | 4 | 23.0
SimCRC
1 | FSIG, 60–75, 20 | 438 | 94 | | | ---
2 | FSIG, 40–75, 20 | 619 | 162 | 181 | 68 | 2.6
3 | FSIG, 40–75, 10 | 910 | 213 | 291 | 51 | 5.7
4 | FSIG, 40–75, 5 | 1,122 | 241 | 212 | 28 | 7.5
5 | FSIG, 40–85, 5 | 1,190 | 243 | 68 | 2 | 38.5

* COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best non-efficient strategy.

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Table 6 Flexible sigmoidoscopy + Hemoccult SENSA strategies

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
| | COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
1 | FSIG+SENSA, 60–75, 20,3 | 1,817 | 163 | | | ---
2 | FSIG+SENSA, 60–75, 10,3 | 1,933 | 171 | | | Near-efficient
3 | FSIG+SENSA, 60–75, 5,3 | 2,031 | 179 | 213 | 15 | 14.0
4 | FSIG+SENSA, 50–75, 20,3 | 2,658 | 213 | | | Near-efficient
5 | FSIG+SENSA, 50–75, 10,3 | 2,756 | 221 | | | Near-efficient
6 | FSIG+SENSA, 50–75, 5,3 | 2,870 | 230 | 839 | 52 | 16.3
7 | FSIG+SENSA, 50–85, 5,3 | 3,042 | 233 | | | Near-efficient
8 | FSIG+SENSA, 50–75, 5,2 | 3,142 | 235 | | | Near-efficient
9 | FSIG+SENSA, 50–85, 10, 2 | 3,245 | 232 | | | Near-efficient
10 | FSIG+SENSA, 50–85, 5,2 | 3,321 | 237 | | | Near-efficient
11 | FSIG+SENSA, 40–75, 5,3 | 3,592 | 249 | 722 | 19 | 38.8
12 | FSIG+SENSA, 40–85, 5,3 | 3,771 | 251 | 178 | 3 | 67.1
13 | FSIG+SENSA, 40–75, 5,2 | 3,987 | 253 | | | Near-efficient
14 | FSIG+SENSA, 40–85, 5,2 | 4,154 | 255 | 384 | 4 | 104.3
15 | FSIG+SENSA, 40–75, 10,1 | 4,568 | 254 | | | Near-efficient
16 | FSIG+SENSA, 40–75, 5,1 | 4,625 | 256 | | | Near-efficient
17 | FSIG+SENSA, 40–85, 5,1 | 4,784 | 256 | 630 | 1 | 454.8
SimCRC
1 | FSIG+SENSA, 60–75, 20,3 | 956 | 152 | | | ---
2 | FSIG+SENSA, 60–75, 10,3 | 999 | 161 | 44 | 9 | 4.7
3 | FSIG+SENSA, 60–75, 5,3 | 1,045 | 169 | 45 | 8 | 5.5
4 | FSIG+SENSA, 50–75, 10,3 | 1,621 | 246 | | | Near-efficient
5 | FSIG+SENSA, 50–75, 5,3 | 1,655 | 257 | 611 | 88 | 7.0
6 | FSIG+SENSA, 40–75, 5,3 | 2,334 | 311 | 678 | 54 | 12.5
7 | FSIG+SENSA, 40–85, 5,3 | 2,619 | 314 | | | Near-efficient
8 | FSIG+SENSA, 40–75, 10,2 | 2,817 | 312 | | | Near-efficient
9 | FSIG+SENSA, 40–75, 5,2 | 2,824 | 320 | 490 | 8 | 59.2
10 | FSIG+SENSA, 40–85, 5,2 | 3,144 | 322 | 321 | 3 | 120.0
11 | FSIG+SENSA, 40–85, 10,2 | 3,145 | 316
12 | FSIG+SENSA, 40–75, 20,1 | 3,680 | 322 | | | Near-efficient
13 | FSIG+SENSA, 40–75, 10,1 | 3,682 | 324 | | | Near-efficient
14 | FSIG+SENSA, 40–75, 5,1 | 3,684 | 326 | 540 | 4 | 134.5
15 | FSIG+SENSA, 40–85, 20,1 | 4,018 | 324 | | | Near-efficient
16 | FSIG+SENSA, 40–85, 10,1 | 4,018 | 326 | | | Near-efficient
17 | FSIG+SENSA, 40–85, 5,1 | 4,018 | 328 | 334 | 2 | 168.7

* COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best nonefficient strategy. Bold indicates recommendable strategy

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.