# Appendix 2: Summary results per 1000 40-year old individuals for all strategies and both models

Table 1. Summary results for all colonoscopy strategies per 1000 40-year old individuals, MISCAN

Table 2. Summary results for all colonoscopy strategies per 1000 40-year old individuals, SimCRC

Table 3. Summary results for all Hemoccult II strategies per 1000 40-year old individuals, MISCAN

Table 4. Summary results for all Hemoccult II strategies per 1000 40-year old individuals, SimCRC

Table 5. Summary results for all Hemoccult SENSA strategies per 1000 40-year old individuals, MISCAN

Table 6. Summary results for all Hemoccult SENSA strategies per 1000 40-year old individuals, SimCRC

Table 7. Summary results for all FIT strategies per 1000 40-year old individuals, MISCAN

Table 8. Summary results for all FIT strategies per 1000 40-year old individuals, SimCRC

Table 9. Summary results for all flexible sigmoidoscopy strategies per 1000 40-year old individuals, MISCAN

Table 10. Summary results for all flexible sigmoidoscopy strategies per 1000 40-year old individuals, SimCRC

Table 11. Summary results for all combinations of Hemoccult SENSA with flexible sigmoidoscopy strategies per 1000 40-year old individuals, MISCAN

Table 12. Summary results for all combinations of flexible sigmoidoscopy and Hemoccult SENSA strategies per 1000 40-year old individuals, SimCRC

Table 1 Summary results for all colonoscopy strategies per 1000 40-year old individuals, MISCAN

Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths† | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 68 | 30 | 0 | -- | --
COL, 40–75, 5 | 7,881 | 0 | 7,881 | 5,451 | 0 | 2,430 | 7.9 | 27 | 8 | 276 | 59.7 | 73.5
COL, 40–75, 10 | 5,231 | 0 | 5,231 | 3,093 | 0 | 2,138 | 5.2 | 32 | 10 | 242 | 52.9 | 65.9
COL, 40–75, 20 | 3,456 | 0 | 3,456 | 1,836 | 0 | 1,620 | 3.5 | 40 | 15 | 185 | 41.5 | 52.0
COL, 40–85, 5 | 8,445 | 0 | 8,445 | 5,970 | 0 | 2,476 | 8.4 | 26 | 7 | 279 | 61.7 | 75.8
COL, 40–85, 10 | 5,629 | 0 | 5,629 | 3,426 | 0 | 2,203 | 5.6 | 30 | 9 | 248 | 55.6 | 69.2
COL, 40–85, 20 | 3,967 | 0 | 3,967 | 2,216 | 0 | 1,751 | 4.0 | 36 | 13 | 195 | 46.5 | 58.2
COL, 50–75, 5 | 5,895 | 0 | 5,895 | 3,770 | 0 | 2,125 | 5.9 | 29 | 9 | 254 | 57.7 | 71.2
COL, 50–75, 10 | 4,136 | 0 | 4,136 | 2,188 | 0 | 1,948 | 4.1 | 33 | 11 | 230 | 51.9 | 64.6
COL, 50–75, 20 | 3,325 | 0 | 3,325 | 1,571 | 0 | 1,754 | 3.3 | 36 | 12 | 203 | 46.6 | 58.8
COL, 50–85, 5 | 6,460 | 0 | 6,460 | 4,289 | 0 | 2,171 | 6.5 | 27 | 8 | 257 | 59.7 | 73.4
COL, 50–85, 10 | 4,534 | 0 | 4,534 | 2,521 | 0 | 2,013 | 4.5 | 31 | 10 | 236 | 54.6 | 67.9
COL, 50–85, 20 | 3,325 | 0 | 3,325 | 1,571 | 0 | 1,754 | 3.3 | 36 | 12 | 203 | 46.6 | 58.8
COL, 60–75, 5 | 3,960 | 0 | 3,960 | 2,390 | 0 | 1,570 | 4.0 | 34 | 11 | 196 | 50.5 | 63.0
COL, 60–75, 10 | 2,899 | 0 | 2,899 | 1,451 | 0 | 1,448 | 2.9 | 37 | 13 | 180 | 45.7 | 57.6
COL, 60–75, 20 | 2,175 | 0 | 2,175 | 917 | 0 | 1,258 | 2.2 | 42 | 16 | 156 | 38.4 | 48.2
COL, 60–85, 5 | 4,525 | 0 | 4,525 | 2,909 | 0 | 1,616 | 4.5 | 32 | 11 | 200 | 52.5 | 65.3
COL, 60–85, 10 | 3,300 | 0 | 3,300 | 1,785 | 0 | 1,515 | 3.3 | 35 | 12 | 186 | 48.5 | 60.9
COL, 60–85, 20 | 2,693 | 0 | 2,693 | 1,300 | 0 | 1,393 | 2.7 | 38 | 14 | 166 | 43.5 | 54.6

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Includes screening related deaths

Table 2 Summary results for all colonoscopy strategies per 1000 40-year old individuals, SimCRC

Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths† | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 64 | 30 | 0 | -- | --
COL, 40–75, 5 | 7,578 | 0 | 7,578 | 5,555 | 0 | 2,021 | 7.6 | 4 | 1 | 331 | 93.2 | 95.5
COL, 40–75, 10 | 4,887 | 0 | 4,887 | 3,130 | 0 | 1,757 | 4.9 | 8 | 3 | 320 | 87.6 | 91.0
COL, 40–75, 20 | 3,131 | 0 | 3,131 | 1,807 | 0 | 1,324 | 3.1 | 17 | 7 | 275 | 72.8 | 76.4
COL, 40–85, 5 | 8,036 | 0 | 8,036 | 5,975 | 0 | 2,062 | 8.0 | 4 | 1 | 332 | 93.9 | 96.2
COL, 40–85, 10 | 5,245 | 0 | 5,245 | 3,423 | 0 | 1,821 | 5.2 | 6 | 2 | 322 | 89.3 | 92.6
COL, 40–85, 20 | 3,627 | 0 | 3,627 | 2,166 | 0 | 1,460 | 3.6 | 15 | 6 | 280 | 77.1 | 81.0
COL, 50–75, 5 | 5,572 | 0 | 5,572 | 3,836 | 0 | 1,735 | 5.6 | 10 | 3 | 282 | 85.6 | 88.6
COL, 50–75, 10 | 3,756 | 0 | 3,756 | 2,236 | 0 | 1,520 | 3.8 | 12 | 5 | 271 | 80.6 | 84.4
COL, 50–75, 20 | 2,885 | 0 | 2,885 | 1,585 | 0 | 1,300 | 2.9 | 18 | 7 | 246 | 72.6 | 77.3
COL, 50–85, 5 | 6,031 | 0 | 6,031 | 4,256 | 0 | 1,776 | 6.0 | 9 | 3 | 282 | 86.4 | 89.3
COL, 50–85, 10 | 4,114 | 0 | 4,114 | 2,530 | 0 | 1,584 | 4.1 | 12 | 4 | 273 | 82.3 | 86.0
COL, 50–85, 20 | 2,885 | 0 | 2,885 | 1,585 | 0 | 1,300 | 2.9 | 18 | 7 | 246 | 72.6 | 77.3
COL, 60–75, 5 | 3,640 | 0 | 3,640 | 2,346 | 0 | 1,294 | 3.6 | 20 | 8 | 191 | 68.6 | 72.5
COL, 60–75, 10 | 2,576 | 0 | 2,576 | 1,437 | 0 | 1,139 | 2.6 | 23 | 9 | 184 | 64.5 | 69.0
COL, 60–75, 20 | 1,780 | 0 | 1,780 | 888 | 0 | 891 | 1.8 | 29 | 12 | 165 | 54.9 | 58.8
COL, 60–85, 5 | 4,099 | 0 | 4,099 | 2,765 | 0 | 1,334 | 4.1 | 20 | 8 | 192 | 69.4 | 73.2
COL, 60–85, 10 | 2,937 | 0 | 2,937 | 1,732 | 0 | 1,205 | 2.9 | 21 | 9 | 186 | 66.2 | 70.6
COL, 60–85, 20 | 2,284 | 0 | 2,284 | 1,252 | 0 | 1,031 | 2.3 | 26 | 11 | 170 | 59.4 | 63.6

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Includes screening related deaths

Table 3 Summary results for all Hemoccult II strategies per 1000 40-year old individuals, MISCAN

Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests† | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 68 | 30 | 0 | -- | --
HII, 40–75, 1 | 24,581 | 21,932 | 2,649 | 21,932 | 590 | 2,059 | 2.6 | 40 | 12 | 219 | 41.5 | 59.6
HII, 40–75, 2 | 14,982 | 13,201 | 1,781 | 13,201 | 396 | 1,385 | 1.8 | 47 | 16 | 169 | 30.5 | 46.7
HII, 40–75, 3 | 10,833 | 9,480 | 1,353 | 9,480 | 301 | 1,053 | 1.4 | 52 | 19 | 137 | 24.2 | 38.0
HII, 40–85, 1 | 26,544 | 23,702 | 2,842 | 23,702 | 646 | 2,197 | 2.8 | 38 | 11 | 225 | 43.4 | 63.3
HII, 40–85, 2 | 16,642 | 14,689 | 1,953 | 14,689 | 455 | 1,499 | 2.0 | 46 | 15 | 178 | 32.7 | 51.6
HII, 40–85, 3 | 12,386 | 10,862 | 1,524 | 10,862 | 363 | 1,162 | 1.5 | 50 | 17 | 147 | 26.5 | 43.5
HII, 50–75, 1 | 18,214 | 16,231 | 1,982 | 16,231 | 495 | 1,487 | 2.0 | 43 | 14 | 194 | 37.1 | 55.3
HII, 50–75, 2 | 10,845 | 9,509 | 1,335 | 9,509 | 328 | 1,008 | 1.3 | 50 | 17 | 149 | 26.8 | 42.7
HII, 50–75, 3 | 7,974 | 6,941 | 1,033 | 6,941 | 254 | 779 | 1.0 | 53 | 20 | 121 | 21.5 | 35.3
HII, 50–85, 1 | 20,594 | 18,409 | 2,186 | 18,409 | 564 | 1,622 | 2.2 | 41 | 12 | 202 | 39.4 | 59.8
HII, 50–85, 2 | 12,675 | 11,162 | 1,513 | 11,162 | 393 | 1,120 | 1.5 | 48 | 16 | 158 | 29.3 | 48.1
HII, 50–85, 3 | 9,265 | 8,089 | 1,176 | 8,089 | 306 | 870 | 1.2 | 52 | 18 | 129 | 23.5 | 39.9
HII, 60–75, 1 | 11,468 | 10,181 | 1,288 | 10,181 | 369 | 918 | 1.3 | 48 | 17 | 141 | 28.9 | 45.4
HII, 60–75, 2 | 6,637 | 5,784 | 854 | 5,784 | 238 | 616 | 0.9 | 54 | 20 | 105 | 20.1 | 33.8
HII, 60–75, 3 | 5,117 | 4,436 | 681 | 4,436 | 193 | 488 | 0.7 | 57 | 22 | 89 | 16.5 | 28.9
HII, 60–85, 1 | 14,400 | 12,886 | 1,514 | 12,886 | 458 | 1,056 | 1.5 | 46 | 15 | 151 | 32.0 | 51.3
HII, 60–85, 2 | 8,693 | 7,645 | 1,048 | 7,645 | 315 | 733 | 1.0 | 52 | 18 | 117 | 23.2 | 40.4
HII, 60–85, 3 | 6,428 | 5,603 | 825 | 5,603 | 249 | 576 | 0.8 | 55 | 20 | 97 | 18.5 | 33.8

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer;Hii = Hemoccult II; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive Hemoccult II.

‡ Includes screening-related deaths

Table 4 Summary results for all Hemoccult II strategies per 1000 40-year old individuals, SimCRC

| Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests† | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 64 | 30 | 0 | -- | --
HII, 40–75, 1 | 24,050 | 21,967 | 2,083 | 22,476 | 556 | 1,018 | 2.1 | 21 | 6 | 275 | 67.3 | 78.4
HII, 40–75, 2 | 14,469 | 13,142 | 1,327 | 13,425 | 361 | 683 | 1.4 | 33 | 12 | 211 | 49.0 | 61.3
HII, 40–75, 3 | 10,389 | 9,399 | 990 | 9,603 | 269 | 517 | 1.0 | 39 | 15 | 167 | 38.2 | 49.0
HII, 40–85, 1 | 25,969 | 23,615 | 2,354 | 24,269 | 609 | 1,091 | 2.3 | 20 | 5 | 280 | 69.8 | 81.9
HII, 40–85, 2 | 16,061 | 14,525 | 1,536 | 14,897 | 414 | 750 | 1.6 | 31 | 10 | 216 | 51.2 | 65.4
HII, 40–85, 3 | 11,825 | 10,660 | 1,165 | 10,926 | 322 | 577 | 1.2 | 39 | 14 | 172 | 39.9 | 53.2
HII, 50–75, 1 | 17,695 | 16,239 | 1,456 | 16,465 | 452 | 778 | 1.5 | 28 | 9 | 218 | 56.6 | 69.0
HII, 50–75, 2 | 10,343 | 9,422 | 921 | 9,545 | 287 | 511 | 0.9 | 39 | 14 | 162 | 39.6 | 52.3
HII, 50–75, 3 | 7,533 | 6,834 | 699 | 6,924 | 218 | 391 | 0.7 | 45 | 17 | 129 | 30.9 | 42.3
HII, 50–85, 1 | 19,974 | 18,262 | 1,712 | 18,603 | 518 | 853 | 1.7 | 26 | 8 | 223 | 59.2 | 73.0
HII, 50–85, 2 | 12,071 | 10,956 | 1,115 | 11,148 | 346 | 577 | 1.1 | 37 | 13 | 168 | 41.9 | 56.8
HII, 50–85, 3 | 8,727 | 7,886 | 841 | 8,024 | 263 | 440 | 0.8 | 43 | 16 | 133 | 32.4 | 45.9
HII, 60–75, 1 | 10,913 | 10,043 | 870 | 10,101 | 322 | 490 | 0.9 | 39 | 15 | 134 | 38.5 | 51.3
HII, 60–75, 2 | 6,180 | 5,640 | 540 | 5,670 | 199 | 311 | 0.5 | 48 | 19 | 95 | 25.5 | 37.0
HII, 60–75, 3 | 4,716 | 4,291 | 425 | 4,314 | 158 | 244 | 0.4 | 51 | 21 | 75 | 19.9 | 29.9
HII, 60–85, 1 | 13,663 | 12,550 | 1,113 | 12,687 | 405 | 571 | 1.1 | 38 | 13 | 141 | 41.6 | 56.2
HII, 60–85, 2 | 8,079 | 7,357 | 722 | 7,431 | 267 | 381 | 0.7 | 47 | 17 | 102 | 28.0 | 42.2
HII, 60–85, 3 | 5,895 | 5,343 | 552 | 5,399 | 205 | 291 | 0.5 | 51 | 20 | 78 | 21.1 | 33.2

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; HII = Hemoccult II; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive Hemoccult II.

‡ Includes screening-related deaths

Table 5 Summary results for all Hemoccult SENSA strategies per 1000 40-year old individuals, MISCAN

Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests† | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 68 | 30 | 0 | -- | --
SENSA, 40–75, 1 | 15,701 | 11,284 | 4,416 | 11,284 | 925 | 3,492 | 4.4 | 32 | 9 | 251 | 53.4 | 68.9
SENSA, 40–75, 2 | 12,379 | 8,877 | 3,503 | 8,877 | 766 | 2,736 | 3.5 | 36 | 11 | 230 | 46.8 | 63.4
SENSA, 40–75, 3 | 10,065 | 7,181 | 2,884 | 7,181 | 641 | 2,243 | 2.9 | 40 | 13 | 206 | 40.7 | 57.0
SENSA, 40–85, 1 | 16,023 | 11,440 | 4,583 | 11,440 | 939 | 3,644 | 4.6 | 31 | 9 | 252 | 54.1 | 69.8
SENSA, 40–85, 2 | 13,020 | 9,326 | 3,695 | 9,326 | 809 | 2,885 | 3.7 | 35 | 10 | 234 | 48.1 | 65.8
SENSA, 40–85, 3 | 10,899 | 7,794 | 3,104 | 7,794 | 705 | 2,400 | 3.1 | 39 | 12 | 212 | 42.7 | 60.8
SENSA, 50–75, 1 | 12,891 | 9,542 | 3,350 | 9,542 | 839 | 2,511 | 3.3 | 34 | 10 | 230 | 49.7 | 66.0
SENSA, 50–75, 2 | 9,599 | 7,014 | 2,584 | 7,014 | 655 | 1,929 | 2.6 | 40 | 12 | 205 | 41.7 | 59.0
SENSA, 50–75, 3 | 7,717 | 5,596 | 2,121 | 5,596 | 543 | 1,579 | 2.1 | 44 | 14 | 181 | 35.9 | 52.8
SENSA, 50–85, 1 | 13,442 | 9,904 | 3,538 | 9,904 | 871 | 2,667 | 3.5 | 34 | 10 | 232 | 50.7 | 67.4
SENSA, 50–85, 2 | 10,480 | 7,679 | 2,801 | 7,679 | 719 | 2,082 | 2.8 | 38 | 11 | 211 | 43.7 | 62.4
SENSA, 50–85, 3 | 8,534 | 6,205 | 2,329 | 6,205 | 606 | 1,723 | 2.3 | 42 | 13 | 188 | 37.9 | 56.6
SENSA, 60–75, 1 | 9,258 | 7,034 | 2,223 | 7,034 | 679 | 1,544 | 2.2 | 40 | 13 | 174 | 40.6 | 56.6
SENSA, 60–75, 2 | 6,379 | 4,732 | 1,647 | 4,732 | 491 | 1,156 | 1.6 | 46 | 16 | 149 | 32.2 | 48.3
SENSA, 60–75, 3 | 5,187 | 3,824 | 1,363 | 3,824 | 413 | 950 | 1.4 | 49 | 17 | 134 | 27.7 | 43.7
SENSA, 60–85, 1 | 10,314 | 7,852 | 2,462 | 7,852 | 751 | 1,711 | 2.5 | 39 | 12 | 179 | 42.5 | 59.5
SENSA, 60–85, 2 | 7,637 | 5,729 | 1,908 | 5,729 | 589 | 1,318 | 1.9 | 44 | 14 | 158 | 35.2 | 53.5
SENSA, 60–85, 3 | 6,145 | 4,561 | 1,584 | 4,561 | 492 | 1,092 | 1.6 | 48 | 16 | 141 | 30.1 | 48.3

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive Hemoccult SENSA.

‡ Includes screening-related deaths

Table 6 Summary results for all Hemoccult SENSA strategies per 1000 40-year old individuals, SimCRC

Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests† | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 64 | 30 | 0 | -- | --
SENSA, 40–75, 1 | 14,994 | 11,294 | 3,700 | 12,566 | 909 | 1,519 | 3.7 | 11 | 3 | 315 | 83.4 | 89.3
SENSA, 40–75, 2 | 11,713 | 8,884 | 2,829 | 9,734 | 743 | 1,236 | 2.9 | 17 | 5 | 287 | 73.3 | 82.3
SENSA, 40–75, 3 | 9,465 | 7,161 | 2,304 | 7,819 | 614 | 1,032 | 2.3 | 23 | 8 | 256 | 63.8 | 74.1
SENSA, 40–85, 1 | 15,493 | 11,454 | 4,039 | 12,985 | 923 | 1,585 | 4.0 | 10 | 3 | 317 | 85.2 | 91.2
SENSA, 40–85, 2 | 12,471 | 9,304 | 3,167 | 10,374 | 784 | 1,313 | 3.2 | 16 | 4 | 291 | 75.7 | 85.3
SENSA, 40–85, 3 | 10,338 | 7,723 | 2,615 | 8,554 | 672 | 1,112 | 2.6 | 22 | 7 | 261 | 66.3 | 77.9
SENSA, 50–75, 1 | 12,227 | 9,573 | 2,654 | 10,203 | 810 | 1,214 | 2.7 | 17 | 6 | 259 | 73.2 | 81.2
SENSA, 50–75, 2 | 8,963 | 7,006 | 1,957 | 7,400 | 620 | 943 | 1.9 | 24 | 8 | 228 | 61.4 | 72.5
SENSA, 50–75, 3 | 7,141 | 5,554 | 1,587 | 5,857 | 505 | 779 | 1.6 | 31 | 11 | 201 | 52.4 | 64.6
SENSA, 50–85, 1 | 12,914 | 9,918 | 2,996 | 10,790 | 840 | 1,284 | 3.0 | 16 | 5 | 262 | 75.3 | 83.3
SENSA, 50–85, 2 | 9,916 | 7,630 | 2,286 | 8,209 | 680 | 1,027 | 2.3 | 23 | 7 | 233 | 64.1 | 76.1
SENSA, 50–85, 3 | 7,987 | 6,124 | 1,863 | 6,569 | 565 | 853 | 1.9 | 29 | 9 | 205 | 54.8 | 68.3
SENSA, 60–75, 1 | 8,607 | 6,977 | 1,630 | 7,165 | 635 | 807 | 1.6 | 30 | 11 | 169 | 53.6 | 63.8
SENSA, 60–75, 2 | 5,803 | 4,657 | 1,146 | 4,764 | 448 | 591 | 1.1 | 38 | 14 | 142 | 42.0 | 54.2
SENSA, 60–75, 3 | 4,669 | 3,735 | 934 | 3,811 | 370 | 488 | 0.9 | 42 | 16 | 123 | 35.3 | 47.6
SENSA, 60–85, 1 | 9,720 | 7,741 | 1,979 | 8,126 | 703 | 891 | 2.0 | 28 | 10 | 173 | 56.3 | 66.7
SENSA, 60–85, 2 | 7,055 | 5,589 | 1,466 | 5,830 | 539 | 686 | 1.5 | 35 | 12 | 149 | 45.4 | 59.0
SENSA, 60–85, 3 | 5,600 | 4,410 | 1,190 | 4,595 | 442 | 563 | 1.2 | 40 | 14 | 128 | 37.6 | 51.6

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive Hemoccult SENSA.

‡ Includes screening-related deaths

Table 7 Summary results for all FIT strategies per 1000 40-year old individuals, MISCAN

Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests† | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 68 | 30 | 0 | -- | --
FIT, 40–75, 1 | 18,587 | 14,667 | 3,921 | 14,667 | 846 | 3,075 | 3.9 | 33 | 10 | 249 | 51.4 | 67.9
FIT, 40–75, 2 | 13,388 | 10,443 | 2,945 | 10,443 | 651 | 2,294 | 2.9 | 39 | 12 | 221 | 42.8 | 60.5
FIT, 40–75, 3 | 10,417 | 8,050 | 2,368 | 8,050 | 527 | 1,841 | 2.4 | 43 | 14 | 194 | 36.4 | 53.3
FIT, 40–85, 1 | 19,248 | 15,144 | 4,104 | 15,144 | 876 | 3,229 | 4.1 | 32 | 9 | 252 | 52.4 | 69.5
FIT, 40–85, 2 | 14,341 | 11,200 | 3,141 | 11,200 | 705 | 2,436 | 3.1 | 38 | 11 | 228 | 44.6 | 63.9
FIT, 40–85, 3 | 11,495 | 8,915 | 2,580 | 8,915 | 595 | 1,985 | 2.6 | 42 | 13 | 203 | 38.7 | 58.1
FIT, 50–75, 1 | 14,721 | 11,772 | 2,949 | 11,772 | 743 | 2,205 | 2.9 | 36 | 11 | 227 | 47.2 | 64.6
FIT, 50–75, 2 | 10,099 | 7,915 | 2,184 | 7,915 | 547 | 1,637 | 2.2 | 42 | 13 | 198 | 38.2 | 56.2
FIT, 50–75, 3 | 7,858 | 6,090 | 1,769 | 6,090 | 444 | 1,324 | 1.8 | 46 | 15 | 173 | 32.4 | 49.7
FIT, 50–85, 1 | 15,737 | 12,582 | 3,155 | 12,582 | 794 | 2,361 | 3.2 | 35 | 10 | 231 | 48.8 | 67.0
FIT, 50–85, 2 | 11,292 | 8,896 | 2,396 | 8,896 | 618 | 1,779 | 2.4 | 40 | 12 | 206 | 40.5 | 60.6
FIT, 50–85, 3 | 8,841 | 6,882 | 1,960 | 6,882 | 508 | 1,451 | 2.0 | 44 | 14 | 180 | 34.6 | 54.2
FIT, 60–75, 1 | 10,052 | 8,113 | 1,939 | 8,113 | 580 | 1,359 | 1.9 | 42 | 14 | 171 | 38.2 | 54.9
FIT, 60–75, 2 | 6,502 | 5,099 | 1,403 | 5,099 | 406 | 997 | 1.4 | 48 | 16 | 144 | 29.6 | 46.1
FIT, 60–75, 3 | 5,194 | 4,036 | 1,158 | 4,036 | 340 | 818 | 1.2 | 51 | 18 | 129 | 25.3 | 41.6
FIT, 60–85, 1 | 11,677 | 9,489 | 2,188 | 9,489 | 667 | 1,521 | 2.2 | 40 | 12 | 178 | 40.7 | 58.9
FIT, 60–85, 2 | 8,032 | 6,386 | 1,647 | 6,386 | 501 | 1,145 | 1.6 | 46 | 15 | 155 | 32.8 | 52.0
FIT, 60–85, 3 | 6,274 | 4,919 | 1,355 | 4,919 | 413 | 942 | 1.4 | 49 | 16 | 137 | 27.7 | 46.7

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive FIT.

‡ Includes screening-related deaths

Table 8 Summary results for all FIT strategies per 1000 40-year old individuals, SimCRC

| Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests† | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 64 | 30 | 0 | -- | --
FIT, 40–75, 1 | 17,941 | 14,705 | 3,236 | 15,711 | 825 | 1,405 | 3.2 | 12 | 4 | 313 | 81.2 | 88.3
FIT, 40–75, 2 | 12,782 | 10,452 | 2,330 | 11,076 | 621 | 1,085 | 2.4 | 20 | 6 | 279 | 68.7 | 79.4
FIT, 40–75, 3 | 9,875 | 8,029 | 1,846 | 8,498 | 495 | 882 | 1.9 | 26 | 9 | 244 | 58.4 | 70.1
FIT, 40–85, 1 | 18,725 | 15,157 | 3,568 | 16,398 | 853 | 1,474 | 3.6 | 11 | 3 | 316 | 83.2 | 90.5
FIT, 40–85, 2 | 13,796 | 11,160 | 2,636 | 11,960 | 673 | 1,163 | 2.7 | 18 | 5 | 283 | 71.2 | 82.9
FIT, 40–85, 3 | 10,942 | 8,824 | 2,118 | 9,425 | 558 | 959 | 2.1 | 25 | 8 | 250 | 60.9 | 74.4
FIT, 50–75, 1 | 14,125 | 11,830 | 2,295 | 12,308 | 709 | 1,108 | 2.3 | 19 | 6 | 256 | 70.8 | 80.0
FIT, 50–75, 2 | 9,522 | 7,908 | 1,614 | 8,190 | 507 | 825 | 1.6 | 27 | 9 | 222 | 57.4 | 69.9
FIT, 50–75, 3 | 7,333 | 6,047 | 1,286 | 6,259 | 405 | 669 | 1.3 | 33 | 11 | 193 | 48.2 | 61.6
FIT, 50–85, 1 | 15,210 | 12,587 | 2,623 | 13,270 | 757 | 1,183 | 2.6 | 17 | 5 | 260 | 73.1 | 82.6
FIT, 50–85, 2 | 10,733 | 8,828 | 1,905 | 9,250 | 575 | 908 | 1.9 | 25 | 8 | 227 | 60.2 | 74.0
FIT, 50–85, 3 | 8,305 | 6,786 | 1,519 | 7,102 | 464 | 739 | 1.5 | 32 | 10 | 198 | 50.5 | 65.6
FIT, 60–75, 1 | 9,458 | 8,061 | 1,397 | 8,196 | 534 | 728 | 1.4 | 31 | 11 | 167 | 51.4 | 62.5
FIT, 60–75, 2 | 5,972 | 5,020 | 952 | 5,095 | 360 | 517 | 1.0 | 39 | 14 | 138 | 39.2 | 52.2
FIT, 60–75, 3 | 4,715 | 3,943 | 772 | 3,995 | 296 | 424 | 0.8 | 43 | 16 | 118 | 32.5 | 45.5
FIT, 60–85, 1 | 11,059 | 9,338 | 1,721 | 9,628 | 617 | 814 | 1.7 | 30 | 10 | 172 | 54.3 | 66.0
FIT, 60–85, 2 | 7,451 | 6,222 | 1,229 | 6,394 | 450 | 607 | 1.2 | 37 | 13 | 145 | 42.5 | 57.4
FIT, 60–85, 3 | 5,736 | 4,752 | 984 | 4,881 | 363 | 492 | 1.0 | 42 | 15 | 123 | 34.6 | 49.6

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive FIT.

‡ Includes screening-related deaths

Table 9 Summary results for all flexible sigmoidoscopy strategies per 1000 40-year old individuals, MISCAN

| Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests† | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 68 | 30 | 0 | -- | --
FSIG, 40–75, 5 | 8,033 | 5,911 | 2,122 | 5,911 | 347 | 1,775 | 2.1 | 35 | 12 | 219 | 48.2 | 60.2
FSIG, 40–75, 10 | 5,086 | 3,275 | 1,811 | 3,275 | 301 | 1,510 | 1.8 | 40 | 14 | 186 | 41.6 | 52.2
FSIG, 40–75, 20 | 3,159 | 1,869 | 1,290 | 1,869 | 217 | 1,073 | 1.3 | 47 | 19 | 133 | 30.4 | 38.1
FSIG, 40–85, 5 | 8,722 | 6,516 | 2,206 | 6,516 | 383 | 1,823 | 2.2 | 34 | 11 | 222 | 50.2 | 62.6
FSIG, 40–85, 10 | 5,575 | 3,660 | 1,915 | 3,660 | 343 | 1,572 | 1.9 | 38 | 13 | 192 | 44.3 | 55.7
FSIG, 40–85, 20 | 3,796 | 2,302 | 1,494 | 2,302 | 299 | 1,196 | 1.5 | 44 | 17 | 144 | 35.5 | 44.7
FSIG, 50–75, 5 | 6,051 | 4,139 | 1,911 | 4,139 | 342 | 1,569 | 1.9 | 36 | 13 | 203 | 46.8 | 58.5
FSIG, 50–75, 10 | 4,023 | 2,338 | 1,685 | 2,338 | 298 | 1,388 | 1.7 | 40 | 15 | 177 | 40.8 | 51.3
FSIG, 50–75, 20 | 3,103 | 1,636 | 1,467 | 1,636 | 268 | 1,199 | 1.5 | 44 | 17 | 150 | 35.4 | 45.1
FSIG, 50–85, 5 | 6,741 | 4,745 | 1,996 | 4,745 | 379 | 1,617 | 2.0 | 35 | 12 | 207 | 48.8 | 61.0
FSIG, 50–85, 10 | 4,513 | 2,723 | 1,790 | 2,723 | 341 | 1,450 | 1.8 | 38 | 14 | 183 | 43.5 | 54.7
FSIG, 50–85, 20 | 3,103 | 1,636 | 1,468 | 1,636 | 268 | 1,199 | 1.5 | 44 | 17 | 150 | 35.4 | 45.1
FSIG, 60–75, 5 | 4,108 | 2,617 | 1,491 | 2,617 | 323 | 1,168 | 1.5 | 40 | 15 | 159 | 41.0 | 51.9
FSIG, 60–75, 10 | 2,842 | 1,530 | 1,311 | 1,530 | 277 | 1,034 | 1.3 | 44 | 17 | 140 | 35.8 | 45.5
FSIG, 60–75, 20 | 1,964 | 917 | 1,047 | 917 | 204 | 843 | 1.0 | 49 | 20 | 114 | 27.9 | 35.2
FSIG, 60–85, 5 | 4,800 | 3,223 | 1,577 | 3,223 | 360 | 1,217 | 1.6 | 39 | 14 | 162 | 43.1 | 54.4
FSIG, 60–85, 10 | 3,342 | 1,919 | 1,423 | 1,919 | 323 | 1,100 | 1.4 | 42 | 15 | 146 | 38.7 | 49.1
FSIG, 60–85, 20 | 2,615 | 1,354 | 1,261 | 1,354 | 289 | 972 | 1.3 | 45 | 18 | 125 | 33.2 | 41.9

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive sigmoidoscopy.

‡ Includes screening-related deaths

Table 10 Summary results for all flexible sigmoidoscopy strategies per 1000 40-year old individuals, SimCRC

| Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests† | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 64 | 30 | 0 | -- | --
FSIG, 40–75, 5 | 7,480 | 6,358 | 1,122 | 6,384 | 222 | 874 | 1.1 | 22 | 10 | 241 | 64.8 | 67.7
FSIG, 40–75, 10 | 4,322 | 3,412 | 910 | 3,430 | 178 | 714 | 0.9 | 29 | 12 | 213 | 56.2 | 59.6
FSIG, 40–75, 20 | 2,482 | 1,863 | 619 | 1,876 | 110 | 496 | 0.6 | 38 | 17 | 162 | 40.9 | 43.6
FSIG, 40–85, 5 | 8,155 | 6,965 | 1,190 | 6,995 | 252 | 908 | 1.2 | 22 | 9 | 243 | 66.3 | 69.3
FSIG, 40–85, 10 | 4,807 | 3,809 | 998 | 3,831 | 214 | 762 | 1.0 | 27 | 11 | 216 | 58.6 | 62.3
FSIG, 40–85, 20 | 3,053 | 2,294 | 759 | 2,308 | 174 | 571 | 0.8 | 35 | 15 | 167 | 45.2 | 48.4
FSIG, 50–75, 5 | 5,478 | 4,483 | 995 | 4,503 | 217 | 758 | 1.0 | 26 | 11 | 199 | 59.0 | 62.2
FSIG, 50–75, 10 | 3,263 | 2,455 | 808 | 2,468 | 174 | 621 | 0.8 | 31 | 14 | 176 | 51.1 | 54.7
FSIG, 50–75, 20 | 2,324 | 1,662 | 662 | 1,670 | 151 | 503 | 0.7 | 37 | 16 | 147 | 42.4 | 46.3
FSIG, 50–85, 5 | 6,152 | 5,088 | 1,064 | 5,114 | 246 | 792 | 1.1 | 25 | 11 | 201 | 60.6 | 63.7
FSIG, 50–85, 10 | 3,746 | 2,849 | 897 | 2,868 | 210 | 668 | 0.9 | 30 | 13 | 180 | 53.6 | 57.3
FSIG, 50–85, 20 | 2,335 | 1,661 | 674 | 1,675 | 151 | 509 | 0.7 | 37 | 16 | 147 | 42.7 | 46.5
FSIG, 60–75, 5 | 3,543 | 2,759 | 784 | 2,771 | 203 | 569 | 0.8 | 34 | 15 | 131 | 46.5 | 49.9
FSIG, 60–75, 10 | 2,185 | 1,553 | 632 | 1,562 | 159 | 464 | 0.6 | 38 | 17 | 116 | 40.0 | 43.5
FSIG, 60–75, 20 | 1,327 | 889 | 438 | 897 | 96 | 334 | 0.4 | 45 | 20 | 94 | 30.1 | 32.5
FSIG, 60–85, 5 | 4,220 | 3,366 | 854 | 3,384 | 232 | 604 | 0.9 | 34 | 15 | 133 | 48.1 | 51.5
FSIG, 60–85, 10 | 2,675 | 1,952 | 723 | 1,965 | 197 | 513 | 0.7 | 37 | 16 | 120 | 42.6 | 46.2
FSIG, 60–85, 20 | 1,906 | 1,323 | 583 | 1,333 | 162 | 411 | 0.6 | 42 | 19 | 99 | 34.4 | 37.4

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive sigmoidoscopy.

‡ Includes screening-related deaths

Table 11 Summary results for all combinations of Hemoccult SENSA with flexible sigmoidoscopy strategies per 1000 40-year old individuals, MISCAN

| Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests | Follow-Up Tests | Surveillance Tests† | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 68 | 30 | 0 | -- | --
FSIG+SENSA, 40–75, 5,1 | 17,268 | 12,643 | 4,625 | 12,643 | 937 | 3,688 | 4.6 | 30 | 9 | 256 | 55.6 | 69.9
FSIG+SENSA, 40–75, 5,2 | 15,169 | 11,181 | 3,987 | 11,181 | 813 | 3,174 | 4.0 | 31 | 9 | 253 | 54.4 | 69.1
FSIG+SENSA, 40–75, 5,3 | 13,754 | 10,162 | 3,592 | 10,162 | 724 | 2,868 | 3.6 | 32 | 10 | 249 | 53.2 | 67.9
FSIG+SENSA, 40–75, 10,1 | 16,599 | 12,031 | 4,568 | 12,031 | 934 | 3,634 | 4.6 | 31 | 9 | 254 | 55.0 | 69.5
FSIG+SENSA, 40–75, 10,2 | 13,941 | 10,068 | 3,873 | 10,068 | 803 | 3,070 | 3.9 | 32 | 10 | 247 | 52.6 | 67.7
FSIG+SENSA, 40–75, 10,3 | 12,143 | 8,702 | 3,441 | 8,702 | 707 | 2,734 | 3.4 | 34 | 10 | 238 | 50.5 | 65.4
FSIG+SENSA, 40–75, 20,1 | 16,393 | 11,882 | 4,512 | 11,882 | 930 | 3,582 | 4.5 | 31 | 9 | 252 | 54.3 | 69.2
FSIG+SENSA, 40–75, 20,2 | 13,389 | 9,653 | 3,735 | 9,653 | 789 | 2,946 | 3.7 | 34 | 10 | 239 | 50.3 | 65.9
FSIG+SENSA, 40–75, 20,3 | 11,330 | 8,090 | 3,240 | 8,090 | 683 | 2,557 | 3.2 | 36 | 11 | 225 | 46.8 | 62.2
FSIG+SENSA, 40–85, 5,1 | 17,562 | 12,778 | 4,784 | 12,778 | 948 | 3,836 | 4.8 | 30 | 9 | 256 | 56.0 | 70.5
FSIG+SENSA, 40–85, 5,2 | 15,795 | 11,641 | 4,154 | 11,641 | 848 | 3,307 | 4.2 | 30 | 9 | 255 | 55.2 | 70.2
FSIG+SENSA, 40–85, 5,3 | 14,575 | 10,804 | 3,771 | 10,804 | 772 | 2,998 | 3.8 | 31 | 9 | 251 | 54.4 | 69.6
FSIG+SENSA, 40–85, 10,1 | 16,908 | 12,179 | 4,729 | 12,179 | 946 | 3,784 | 4.7 | 30 | 9 | 255 | 55.5 | 70.2
FSIG+SENSA, 40–85, 10,2 | 14,558 | 10,509 | 4,048 | 10,509 | 840 | 3,208 | 4.0 | 32 | 9 | 249 | 53.6 | 69.2
FSIG+SENSA, 40–85, 10,3 | 12,948 | 9,315 | 3,633 | 9,315 | 761 | 2,873 | 3.6 | 33 | 10 | 242 | 52.0 | 67.7
FSIG+SENSA, 40–85, 20,1 | 16,715 | 12,037 | 4,677 | 12,037 | 943 | 3,734 | 4.7 | 31 | 9 | 253 | 54.9 | 70.0
FSIG+SENSA, 40–85, 20,2 | 14,051 | 10,123 | 3,928 | 10,123 | 833 | 3,095 | 3.9 | 33 | 10 | 243 | 51.8 | 68.0
FSIG+SENSA, 40–85, 20,3 | 12,208 | 8,744 | 3,464 | 8,744 | 749 | 2,715 | 3.5 | 35 | 10 | 231 | 49.1 | 65.6
FSIG+SENSA, 50–75, 5,1 | 13,914 | 10,279 | 3,635 | 10,279 | 863 | 2,772 | 3.6 | 31 | 10 | 239 | 53.8 | 68.2
FSIG+SENSA, 50–75, 5,2 | 11,730 | 8,588 | 3,142 | 8,588 | 723 | 2,419 | 3.1 | 33 | 10 | 235 | 52.2 | 66.9
FSIG+SENSA, 50–75, 5,3 | 10,555 | 7,685 | 2,870 | 7,685 | 645 | 2,225 | 2.9 | 33 | 10 | 230 | 51.2 | 65.7
FSIG+SENSA, 50–75, 10,1 | 13,329 | 9,738 | 3,591 | 9,738 | 858 | 2,733 | 3.6 | 32 | 10 | 237 | 52.9 | 67.7
FSIG+SENSA, 50–75, 10,2 | 10,751 | 7,697 | 3,054 | 7,697 | 709 | 2,345 | 3.1 | 34 | 11 | 229 | 50.2 | 65.3
FSIG+SENSA, 50–75, 10,3 | 9,329 | 6,573 | 2,756 | 6,573 | 625 | 2,130 | 2.8 | 35 | 11 | 221 | 48.3 | 63.1
FSIG+SENSA, 50–75, 20,1 | 13,149 | 9,590 | 3,558 | 9,590 | 855 | 2,703 | 3.6 | 32 | 10 | 236 | 52.3 | 67.4
FSIG+SENSA, 50–75, 20,2 | 10,390 | 7,407 | 2,983 | 7,407 | 702 | 2,281 | 3.0 | 35 | 11 | 224 | 48.5 | 64.2
FSIG+SENSA, 50–75, 20,3 | 8,851 | 6,192 | 2,658 | 6,192 | 615 | 2,044 | 2.7 | 37 | 12 | 213 | 45.9 | 61.4
FSIG+SENSA, 50–85, 5,1 | 14,419 | 10,611 | 3,808 | 10,611 | 889 | 2,919 | 3.8 | 31 | 9 | 240 | 54.4 | 69.1
FSIG+SENSA, 50–85, 5,2 | 12,589 | 9,267 | 3,321 | 9,267 | 773 | 2,548 | 3.3 | 32 | 10 | 237 | 53.2 | 68.4
FSIG+SENSA, 50–85, 5,3 | 11,422 | 8,380 | 3,042 | 8,380 | 696 | 2,346 | 3.0 | 32 | 10 | 233 | 52.4 | 67.5
FSIG+SENSA, 50–85, 10,1 | 13,850 | 10,081 | 3,768 | 10,081 | 885 | 2,883 | 3.8 | 32 | 9 | 239 | 53.7 | 68.8
FSIG+SENSA, 50–85, 10,2 | 11,596 | 8,350 | 3,245 | 8,350 | 764 | 2,481 | 3.2 | 33 | 10 | 232 | 51.5 | 67.4
FSIG+SENSA, 50–85, 10,3 | 10,160 | 7,217 | 2,942 | 7,217 | 682 | 2,260 | 2.9 | 34 | 10 | 225 | 49.9 | 65.6
FSIG+SENSA, 50–85, 20,1 | 13,649 | 9,915 | 3,734 | 9,915 | 881 | 2,852 | 3.7 | 32 | 10 | 238 | 52.9 | 68.4
FSIG+SENSA, 50–85, 20,2 | 11,140 | 7,980 | 3,159 | 7,980 | 751 | 2,409 | 3.2 | 34 | 10 | 227 | 49.5 | 66.0
FSIG+SENSA, 50–85, 20,3 | 9,522 | 6,703 | 2,818 | 6,703 | 660 | 2,159 | 2.8 | 36 | 11 | 216 | 46.8 | 63.3
FSIG+SENSA, 60–75, 5,1 | 10,067 | 7,544 | 2,523 | 7,544 | 724 | 1,799 | 2.5 | 36 | 12 | 187 | 46.9 | 60.6
FSIG+SENSA, 60–75, 5,2 | 8,037 | 5,850 | 2,187 | 5,850 | 588 | 1,599 | 2.2 | 37 | 12 | 182 | 45.2 | 58.8
FSIG+SENSA, 60–75, 5,3 | 7,251 | 5,220 | 2,031 | 5,220 | 536 | 1,494 | 2.0 | 38 | 13 | 179 | 44.3 | 57.9
FSIG+SENSA, 60–75, 10,1 | 9,607 | 7,128 | 2,479 | 7,128 | 714 | 1,765 | 2.5 | 37 | 12 | 185 | 45.7 | 59.7
FSIG+SENSA, 60–75, 10,2 | 7,330 | 5,225 | 2,106 | 5,225 | 568 | 1,537 | 2.1 | 39 | 13 | 176 | 42.8 | 56.6
FSIG+SENSA, 60–75, 10,3 | 6,431 | 4,497 | 1,933 | 4,497 | 513 | 1,421 | 1.9 | 40 | 14 | 171 | 41.5 | 55.3
FSIG+SENSA, 60–75, 20,1 | 9,401 | 6,963 | 2,438 | 6,963 | 703 | 1,735 | 2.4 | 38 | 13 | 183 | 44.5 | 58.8
FSIG+SENSA, 60–75, 20,2 | 6,939 | 4,924 | 2,015 | 4,924 | 544 | 1,471 | 2.0 | 41 | 14 | 170 | 40.1 | 54.2
FSIG+SENSA, 60–75, 20,3 | 5,960 | 4,142 | 1,817 | 4,142 | 482 | 1,336 | 1.8 | 42 | 15 | 163 | 38.0 | 52.0
FSIG+SENSA, 60–85, 5,1 | 11,035 | 8,309 | 2,726 | 8,309 | 782 | 1,944 | 2.7 | 35 | 12 | 189 | 47.8 | 62.0
FSIG+SENSA, 60–85, 5,2 | 9,242 | 6,856 | 2,386 | 6,856 | 664 | 1,722 | 2.4 | 36 | 12 | 185 | 46.7 | 61.0
FSIG+SENSA, 60–85, 5,3 | 8,305 | 6,097 | 2,209 | 6,097 | 600 | 1,609 | 2.2 | 37 | 12 | 182 | 45.9 | 60.1
FSIG+SENSA, 60–85, 10,1 | 10,594 | 7,901 | 2,694 | 7,901 | 776 | 1,917 | 2.7 | 36 | 12 | 188 | 47.0 | 61.6
FSIG+SENSA, 60–85, 10,2 | 8,520 | 6,196 | 2,324 | 6,196 | 651 | 1,673 | 2.3 | 38 | 12 | 181 | 44.8 | 59.7
FSIG+SENSA, 60–85, 10,3 | 7,414 | 5,283 | 2,130 | 5,283 | 583 | 1,547 | 2.1 | 38 | 13 | 176 | 43.6 | 58.3
FSIG+SENSA, 60–85, 20,1 | 10,446 | 7,775 | 2,671 | 7,775 | 773 | 1,898 | 2.7 | 36 | 12 | 187 | 46.3 | 61.2
FSIG+SENSA, 60–85, 20,2 | 8,231 | 5,957 | 2,274 | 5,957 | 643 | 1,631 | 2.3 | 39 | 13 | 178 | 43.2 | 58.7
FSIG+SENSA, 60–85, 20,3 | 7,036 | 4,974 | 2,061 | 4,974 | 571 | 1,491 | 2.1 | 40 | 13 | 171 | 41.2 | 56.5

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive sigmoidoscopy or Hemoccult SENSA.

‡ Includes screening-related deaths

Table 12 Summary results for all combinations of flexible sigmoidoscopy and Hemoccult SENSA strategies per 1000 40-year old individuals, SimCRC

| Outcomes per 1000 Persons
Strategy Test, Age Begin-Age Stop, Interval* | Total Tests | Non-COL Tests | COL Tests | Screening Tests† | Follow-Up Tests | Surveillance Tests | COMPLIC | Total CRC Cases | CRC Deaths‡ | LYG | % Incidence Reduction | % Mortality Reduction
No Screening | 0 | 0 | 0 | 0 | 0 | 0 | 0.0 | 64 | 30 | 0 | -- | --
FSIG+SENSA, 40–75, 5,1 | 18,606 | 14,922 | 3,684 | 16,189 | 930 | 1,487 | 3.7 | 9 | 3 | 326 | 86.9 | 91.2
FSIG+SENSA, 40–75, 5,2 | 17,269 | 14,445 | 2,824 | 14,854 | 924 | 1,491 | 3.7 | 9 | 3 | 320 | 86.0 | 90.8
FSIG+SENSA, 40–75, 5,3 | 16,603 | 14,269 | 2,334 | 14,193 | 918 | 1,492 | 3.7 | 9 | 3 | 311 | 85.2 | 90.4
FSIG+SENSA, 40–75, 10,1 | 19,102 | 15,420 | 3,682 | 16,611 | 942 | 1,549 | 4.0 | 7 | 2 | 324 | 88.5 | 92.9
FSIG+SENSA, 40–75, 10,2 | 17,769 | 14,952 | 2,817 | 15,278 | 937 | 1,554 | 4.0 | 8 | 2 | 312 | 87.7 | 92.5
FSIG+SENSA, 40–75, 10,3 | 17,116 | 14,803 | 2,313 | 14,626 | 933 | 1,557 | 4.0 | 8 | 2 | 300 | 87.0 | 92.2
FSIG+SENSA, 40–75, 20,1 | 15,656 | 11,976 | 3,680 | 13,616 | 841 | 1,199 | 2.7 | 14 | 5 | 322 | 79.0 | 84.5
FSIG+SENSA, 40–75, 20,2 | 14,450 | 11,643 | 2,807 | 12,425 | 831 | 1,194 | 2.7 | 14 | 5 | 305 | 77.7 | 83.7
FSIG+SENSA, 40–75, 20,3 | 13,907 | 11,617 | 2,290 | 11,888 | 827 | 1,192 | 2.7 | 15 | 5 | 286 | 76.8 | 83.3
FSIG+SENSA, 40–85, 5,1 | 16,340 | 12,322 | 4,018 | 14,210 | 867 | 1,263 | 3.0 | 12 | 4 | 328 | 80.7 | 86.2
FSIG+SENSA, 40–85, 5,2 | 15,144 | 12,000 | 3,144 | 13,023 | 861 | 1,260 | 3.0 | 13 | 4 | 322 | 79.5 | 85.6
FSIG+SENSA, 40–85, 5,3 | 14,568 | 11,949 | 2,619 | 12,454 | 855 | 1,259 | 3.0 | 14 | 4 | 314 | 78.6 | 85.2
FSIG+SENSA, 40–85, 10,1 | 11,495 | 7,477 | 4,018 | 9,994 | 680 | 821 | 1.7 | 25 | 9 | 326 | 61.8 | 68.5
FSIG+SENSA, 40–85, 10,2 | 10,533 | 7,388 | 3,145 | 9,061 | 666 | 806 | 1.6 | 26 | 10 | 316 | 60.2 | 67.4
FSIG+SENSA, 40–85, 10,3 | 10,054 | 7,446 | 2,608 | 8,606 | 654 | 794 | 1.6 | 26 | 10 | 304 | 58.9 | 66.6
FSIG+SENSA, 40–85, 20,1 | 12,602 | 8,584 | 4,018 | 10,972 | 741 | 889 | 2.0 | 23 | 9 | 324 | 63.7 | 70.4
FSIG+SENSA, 40–85, 20,2 | 11,662 | 8,516 | 3,146 | 10,050 | 731 | 881 | 2.0 | 24 | 9 | 309 | 62.4 | 69.8
FSIG+SENSA, 40–85, 20,3 | 11,235 | 8,633 | 2,602 | 9,636 | 724 | 875 | 2.0 | 24 | 9 | 291 | 61.5 | 69.3
FSIG+SENSA, 50–75, 5,1 | 16,259 | 13,593 | 2,666 | 14,281 | 794 | 1,184 | 2.8 | 11 | 3 | 274 | 83.6 | 89.2
FSIG+SENSA, 50–75, 5,2 | 14,259 | 12,265 | 1,994 | 12,289 | 778 | 1,192 | 2.8 | 13 | 4 | 265 | 80.9 | 87.4
FSIG+SENSA, 50–75, 5,3 | 13,278 | 11,623 | 1,655 | 11,319 | 762 | 1,197 | 2.8 | 15 | 4 | 257 | 78.0 | 85.4
FSIG+SENSA, 50–75, 10,1 | 17,056 | 14,403 | 2,653 | 14,976 | 830 | 1,250 | 3.2 | 10 | 3 | 271 | 85.5 | 91.3
FSIG+SENSA, 50–75, 10,2 | 15,048 | 13,077 | 1,971 | 12,969 | 817 | 1,262 | 3.1 | 11 | 3 | 258 | 83.1 | 89.8
FSIG+SENSA, 50–75, 10,3 | 14,106 | 12,485 | 1,621 | 12,028 | 806 | 1,272 | 3.1 | 13 | 3 | 246 | 80.6 | 88.3
FSIG+SENSA, 50–75, 20,1 | 12,861 | 10,214 | 2,647 | 11,258 | 686 | 917 | 2.0 | 16 | 5 | 270 | 75.0 | 81.7
FSIG+SENSA, 50–75, 20,2 | 11,192 | 9,229 | 1,963 | 9,613 | 665 | 914 | 2.0 | 18 | 6 | 252 | 71.7 | 79.5
FSIG+SENSA, 50–75, 20,3 | 10,508 | 8,899 | 1,609 | 8,937 | 656 | 915 | 2.0 | 20 | 7 | 237 | 69.3 | 78.0
FSIG+SENSA, 50–85, 5,1 | 13,871 | 10,875 | 2,996 | 12,148 | 739 | 984 | 2.3 | 15 | 5 | 276 | 77.0 | 84.0
FSIG+SENSA, 50–85, 5,2 | 12,193 | 9,895 | 2,298 | 10,483 | 724 | 986 | 2.3 | 16 | 5 | 268 | 74.2 | 82.3
FSIG+SENSA, 50–85, 5,3 | 11,392 | 9,484 | 1,908 | 9,696 | 709 | 987 | 2.3 | 18 | 6 | 260 | 71.4 | 80.7
FSIG+SENSA, 50–85, 10,1 | 8,781 | 5,794 | 2,987 | 7,650 | 529 | 602 | 1.3 | 28 | 10 | 274 | 57.8 | 65.3
FSIG+SENSA, 50–85, 10,2 | 7,554 | 5,268 | 2,286 | 6,462 | 504 | 588 | 1.2 | 29 | 11 | 262 | 54.3 | 62.7
FSIG+SENSA, 50–85, 10,3 | 6,926 | 5,041 | 1,885 | 5,875 | 479 | 572 | 1.1 | 32 | 12 | 250 | 50.8 | 60.0
FSIG+SENSA, 50–85, 20,1 | 10,114 | 7,133 | 2,981 | 8,834 | 609 | 671 | 1.5 | 26 | 10 | 272 | 59.9 | 67.9
FSIG+SENSA, 50–85, 20,2 | 8,875 | 6,602 | 2,273 | 7,619 | 592 | 664 | 1.5 | 28 | 10 | 256 | 57.1 | 66.2
FSIG+SENSA, 50–85, 20,3 | 8,335 | 6,472 | 1,863 | 7,096 | 579 | 660 | 1.5 | 29 | 11 | 240 | 54.5 | 64.6
FSIG+SENSA, 60–75, 5,1 | 14,599 | 12,912 | 1,687 | 12,919 | 691 | 989 | 2.3 | 13 | 4 | 184 | 80.6 | 86.8
FSIG+SENSA, 60–75, 5,2 | 12,290 | 11,052 | 1,238 | 10,632 | 668 | 990 | 2.3 | 15 | 5 | 176 | 76.5 | 83.8
FSIG+SENSA, 60–75, 5,3 | 11,109 | 10,064 | 1,045 | 9,475 | 643 | 991 | 2.3 | 18 | 6 | 169 | 71.6 | 80.0
FSIG+SENSA, 60–75, 10,1 | 15,553 | 13,894 | 1,659 | 13,761 | 742 | 1,050 | 2.6 | 12 | 3 | 182 | 82.5 | 89.1
FSIG+SENSA, 60–75, 10,2 | 13,225 | 12,028 | 1,197 | 11,444 | 724 | 1,057 | 2.6 | 13 | 4 | 169 | 78.8 | 86.7
FSIG+SENSA, 60–75, 10,3 | 12,103 | 11,104 | 999 | 10,329 | 709 | 1,065 | 2.6 | 16 | 5 | 161 | 74.7 | 83.8
FSIG+SENSA, 60–75, 20,1 | 11,334 | 9,698 | 1,636 | 9,979 | 595 | 760 | 1.7 | 18 | 6 | 180 | 72.2 | 79.3
FSIG+SENSA, 60–75, 20,2 | 9,489 | 8,331 | 1,158 | 8,168 | 569 | 752 | 1.6 | 21 | 7 | 164 | 67.6 | 76.1
FSIG+SENSA, 60–75, 20,3 | 8,719 | 7,763 | 956 | 7,410 | 557 | 752 | 1.6 | 23 | 8 | 152 | 63.9 | 73.6
FSIG+SENSA, 60–85, 5,1 | 12,321 | 10,311 | 2,010 | 10,855 | 650 | 816 | 1.9 | 17 | 5 | 187 | 74.1 | 81.6
FSIG+SENSA, 60–85, 5,2 | 10,436 | 8,916 | 1,520 | 8,994 | 629 | 813 | 1.9 | 19 | 6 | 179 | 70.0 | 78.9
FSIG+SENSA, 60–85, 5,3 | 9,489 | 8,215 | 1,274 | 8,070 | 606 | 813 | 1.9 | 22 | 7 | 172 | 65.7 | 76.1
FSIG+SENSA, 60–85, 10,1 | 7,682 | 5,689 | 1,993 | 6,713 | 469 | 500 | 1.0 | 29 | 11 | 185 | 55.6 | 63.2
FSIG+SENSA, 60–85, 10,2 | 6,381 | 4,885 | 1,496 | 5,457 | 440 | 484 | 1.0 | 32 | 12 | 174 | 51.2 | 59.8
FSIG+SENSA, 60–85, 10,3 | 5,692 | 4,450 | 1,242 | 4,812 | 408 | 472 | 0.9 | 35 | 13 | 165 | 46.4 | 55.7
FSIG+SENSA, 60–85, 20,1 | 8,828 | 6,846 | 1,982 | 7,738 | 536 | 554 | 1.3 | 27 | 10 | 184 | 57.5 | 65.6
FSIG+SENSA, 60–85, 20,2 | 7,475 | 5,996 | 1,479 | 6,416 | 514 | 545 | 1.2 | 30 | 11 | 170 | 53.7 | 63.1
FSIG+SENSA, 60–85, 20,3 | 6,863 | 5,643 | 1,220 | 5,827 | 496 | 540 | 1.2 | 32 | 12 | 158 | 49.8 | 60.2

COL = colonoscopy; COMPLIC = complications; CRC = colorectal cancer; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

† Including colonoscopies for re-screening of individuals with a false-positive sigmoidoscopy or Hemoccult SENSA.

‡ Includes screening-related deaths