# References

1 Espey DK, Wu XC, Swan J, et al. Annual report to the nation on the status of cancer, 1975-2004, featuring cancer in American Indians and Alaska Natives. Cancer. 2007;110(10):2119-52. [pmid: 17939129].
2 Cancer Facts and Figures American Cancer Society, Available at: http://www.cancer.org/downloads/STT/2008CAFFfinalsecured.pdf; 2008.
3 Mandel J, Bond J, Church T, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328(19):1365-71. [pmid: 8474513].
4 Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348(9040):1472-7. [pmid: 8942775].
5 Kronborg O, Fenger C, Olsen J, Jorgensen OD, Sondergaard O. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348(9040):1467-71. [pmid: 8942774].
6 Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: clinical guidelines and rationale. Gastroenterology. 1997;112(2):594-642. [pmid: 9024315].
7 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124(2):544-60. [pmid: 12557158].
8 U.S. Preventive Services Task Force. Screening for colorectal cancer: recommendation and rationale. Ann Intern Med. 2002;137(2):129-31. [pmid: 12118971].
9 Whitlock EP, Lin JS, Liles E, Beil TL, Fu R. Screening for colorectal cancer: a targeted, updated systematic review for the u.s. Preventive services task force. Ann Intern Med. 2008;149(9):638-58. [pmid: 18838718].
10 Whitlock EP, Lin J, Liles E, et al. Screening for colorectal cancer: an updated systematic review. Rockville, MD: Agency for Healthcare Research and Quality. Vol. 2008; 2008.
11 Zauber AG, Lansdorp-Vogelaar I, Knudsen AB, Wilschut J, van Ballegooijen M, Kuntz KM. Evaluating test strategies for colorectal cancer screening: a decision analysis for the u.s. Preventive services task force. Ann Intern Med. 2008;149(9):659-69. [pmid: 18838717].
12 Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JDF. The MISCAN-COLON simulation model for the evaluation of colorectal cancer screening. Comput Biomed Res. 1999;32:13-33. [pmid: 10066353].
13 Loeve F, Brown ML, Boer R, van Ballegooijen M, van Oortmarssen GJ, Habbema JD. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 2000;92(7):557-63. [pmid: 10749911].
14 Vogelaar I, van Ballegooijen M, Schrag D, et al. How much can current interventions reduce colorectal cancer mortality in the U.S.? Mortality projections for scenarios of risk-factor modification, screening, and treatment. Cancer. 2006;107(7):1624-33. [pmid: 16933324].
15 Frazier AL, Colditz GA, Fuchs CS, Kuntz KM. Cost-effectiveness of screening for colorectal cancer in the general population. JAMA. 2000;284(15):1954-61. [pmid: 11035892].
16 Surveillance Epidemiology, and End Results (SEER) Program (http://www.seer.cancer.gov) SEER* Stat Database: Incidence - SEER 9 Regs Public-Use, Nov2003 Sub (1973-2001), National Cancer Institute. DCCPS, Surveillance Research Program, Cancer Statistics Branch, released April 2004, based on the November 2003 submission.
17 Clark JC, Collan Y, Eide TJ, et al. Prevalence of polyps in an autopsy series from areas with varying incidence of large-bowel cancer. Int J Cancer. 1985;36(2):179-86. [pmid: 4018911].
18 Blatt LJ. Polyps of the colon and rectum: incidence and distribution. Dis Colon Rectum. 1961;4:277-282.
19 Vatn MH, Stalsberg H. The prevalence of polyps of the large intestine in Oslo: an autopsy study. Cancer. 1982;49(4):819-25. [pmid: 7055790].
20 Jass JR, Young PJ, Robinson EM. Predictors of presence, multiplicity, size and dysplasia of colorectal adenomas. A necropsy study in New Zealand. Gut. 1992;33:1508-1514. [pmid: 1452076].
21 Johannsen LG, Momsen O, Jacobsen NO. Polyps of the large intestine in Aarhus, Denmark. An autopsy study. Scand J Gastroenterol. 1989;24(7):799-806. [pmid: 2799283].
22 Bombi JA. Polyps of the colon in Barcelona, Spain. Cancer. 1988;61(7):1472-1476. [pmid: 3345499].
23 Williams AR, Balasooriya BA, Day DW. Polyps and cancer of the large bowel: a necropsy study in Liverpool. Gut. 1982;23(10):835-42. [pmid: 7117903].
24 Rickert RR, Auerbach O, Garfinkel L, Hammond EC, Frasca JM. Adenomatous lesions of the large bowel. Cancer. 1979;43:1847-1857. [pmid: 445371].
25 Chapman I. Adenomatous polypi of large intestine: incidence and distribution. Ann Surg. 1963;157:223-226. [pmid: 14020146].
26 Arminski TC, McLean DW. Incidence and distribution of adenomatous polyps of the colon and rectum based on 1.000 autopsy examinations. Dis Colon Rectum. 1964;7:249-61. [pmid: 14176135].
27 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343(22):1603-7. [pmid: 11096167].
28 Mandel JS, Church TR, Ederer F, Bond JH. Colorectal cancer mortality: effectiveness of biennial screening for fecal occult blood. J Natl Cancer Inst. 1999;91(5):434-7. [pmid: 10070942].
29 Zauber AG, Lansdorp-Vogelaar I, Wilschut J, Knudsen AB, van Ballegooijen M, Kuntz KM. Cost-Effectiveness of DNA Stool Testing to Screen for Colorectal Cancer: Report to AHRQ and CMS from the Cancer Intervention and Surveillance Modeling Network (CISNET) for MISCAN and SimCRC Models. Available from: https://www.cms.hhs.gov/mcd/viewtechassess.asp?from2=viewtechassess.asp&id=212&. 2007.
30 Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. Published jointly in Gastroenterology. May 2008;134(5):1570–1595. CA Cancer J Clin. 2008;58(3):130-160. and Radiology 2008. [pmid: 18322143].
31 Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for colonoscopy surveillance after polypectomy: a consensus update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. CA Cancer J Clin. 2006;56(3):143-59. quiz 184–5. [pmid: 16737947].
32 van Ballegooijen M, Habbema JDF, Boer R, Zauber AG, Brown ML. Report to the Agency for Healthcare Research and Quality: a comparison of the cost-effectiveness of fecal occult blood tests with different test characteristics in the context of annual screening in the Medicare population. 2003.
33 Morikawa T, Kato J, Yamaji Y, Wada R, Mitsushima T, Shiratori Y. A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. 2005;129(2):422-8. [pmid: 16083699].
34 van Rijn JC, Reitsma JB, Stoker J, Bossuyt PM, van Deventer SJ, Dekker E. Polyp miss rate determined by tandem colonoscopy: a systematic review. Am J Gastroenterol. 2006;101(2):343-50. [pmid: 16454841].
35 Mark DH. Visualizing cost-effectiveness analysis. JAMA. 2002;287(18):2428-9. [pmid: 11988064].
36 Arias E. United States life tables, 2003. Natl Vital Stat Rep. 2006;54(14):1-40. [pmid: 16681183].
37 Brown ML, Klabunde CN, Mysliwiec P. Current capacity for endoscopic colorectal cancer screening in the United States: data from the National Cancer Institute Survey of Colorectal Cancer Screening Practices. Am J Med. 2003;115(2):129-33. [pmid: 12893399].
38 Mysliwiec PA, Brown ML, Klabunde CN, Ransohoff DF. Are physicians doing too much colonoscopy? A national survey of colorectal surveillance after polypectomy. Ann Intern Med. 2004;141(4):264-71. [pmid: 15313742].
39 Seeff LC, Manninen DL, Dong FB, et al. Is there endoscopic capacity to provide colorectal cancer screening to the unscreened population in the United States?. Gastroenterology. 2004;127(6):1661-9. [pmid: 15578502].
40 Rex DK, Petrini JL, Baron TH, et al. Quality indicators for colonoscopy. Am J Gastroenterol. 2006;101(4):873-85. [pmid: 16635231].
41 Barclay RL, Vicari JJ, Doughty AS, Johanson JF, Greenlaw RL. Colonoscopic withdrawal times and adenoma detection during screening colonoscopy. N Engl J Med. 2006;355(24):2533-41. [pmid: 17167136].
42 Baron R, Rimer BK, Berkowitz J, Harris K. Increasing screening for Breast, Cervical, and Colorectal Cancers - Recommendations from the Task Force on Community Preventive Services, Methods, Systematic Reviews of Evidence and Expert Commentary. Am J Prev Med. 2008;35(1):A1-A4. S1–S76. [pmid: 18482823].