# Acknowledgements

We thank Mary Barton, MD, MPH and William Lawrence, MD, MSc from the Agency for Healthcare Research and Quality; Steve Teutsch, MD, Diana Petitti, MD, Michael Lefevre, MD and George Isham, MD of the US Preventive Services Task Force; Eric (Rocky) Feuer, PhD of the National Cancer Institute; Evelyn Whitlock, M.D., MPH of the Oregon Evidence Based Practice Center; and Laura Seeff, MD, David Ransohoff, MD, and Carolyn Rutter, PhD for helpful comments and review of earlier versions this paper.

[underlined: Potential Financial Conflicts of Interest]: None disclosed.

## Reproducible Research Statement

Models are available to approved individuals with written agreement.