# Results

Table 3 presents the life-years gained, the number of colonoscopies, and the efficiency ratio for each efficient and near-efficient strategy for both models for each test for age to begin screening of 50 or 60. All strategies for each test can be found in Appendix 2 which includes incidence and mortality reductions as well as the number of screening and surveillance tests required for each strategy. The figures of life-years gained relative to the number of colonoscopies and the efficient frontier for each test are given in Figure 2.

Table 3 Efficient and Near-Efficient Strategies for Age to Begin Screening of 50 and 60*

Strategy Test, Age Begin-Age Stop, Interval† | | Outcomes per 1000 Persons
COL | Non-COL Tests | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
Colonoscopy strategies
MISCAN
1 | COL, 60–75, 20 | 2175 | 0 | 156 | - | - | -
2 | COL, 50–75, 20 | 3325 | 0 | 203 | 1150 | 47 | 24.7
3 | COL, 50–75, 10 | 4136 | 0 | 230 | 811 | 27 | 29.6
4 | COL, 50–85, 10 | 4534 | 0 | 236 | 398 | 5 | 72.9
5 | COL, 50–75, 5 | 5895 | 0 | 254 | 1362 | 18 | 74.8
6 | COL, 50–85, 5 | 6460 | 0 | 257 | 565 | 4 | 156.1
SimCRC
1 | COL, 60–75, 20 | 1780 | 0 | 165 | - | - | -
2 | COL, 50–75, 20 | 2885 | 0 | 246 | 1106 | 82 | 13.5
3 | COL, 50–75, 10 | 3756 | 0 | 271 | 871 | 25 | 34.7
4 | COL, 50–85, 10 | 4114 | 0 | 273 | | | Near-efficient
5 | COL, 50–75, 5 | 5572 | 0 | 281.6 | 1816 | 10 | 178.8
6 | COL, 50–85, 5 | 6031 | 0 | 282.1 | 459 | 0.5 | 975.7
Hemoccult II strategies
MISCAN
1 | Hemoccult II, 60–75, 3 | 681 | 4435 | 89 | - | - | -
2 | Hemoccult II, 60–75, 2 | 854 | 5784 | 105 | 172 | 16 | 10.6
3 | Hemoccult II, 50–75, 3 | 1033 | 6941 | 121 | | | Near-efficient
4 | Hemoccult II, 50–75, 2 | 1335 | 9510 | 149 | 482 | 44 | 11.0
5 | Hemoccult II, 50–85, 2 | 1513 | 11,162 | 158 | | | Near-efficient
6 | Hemoccult II, 50–75, 1 | 1982 | 16,232 | 194 | 647 | 45 | 14.3
7 | Hemoccult II, 50–85, 1 | 2186 | 18,409 | 202 | 203 | 8 | 25.5
SimCRC
1 | Hemoccult II, 60–75, 3 | 425 | 4291 | 75 | - | - | -
2 | Hemoccult II, 50–75, 3 | 699 | 6834 | 129 | 275 | 54 | 5.1
3 | Hemoccult II, 50–75, 2 | 921 | 9422 | 162 | 221 | 33 | 6.7
4 | Hemoccult II, 50–75, 1 | 1456 | 16,239 | 218 | 536 | 56 | 9.6
5 | Hemoccult II, 50–85, 1 | 1712 | 18,262 | 223 | 256 | 5 | 47.9
Hemoccult SENSA strategies
MISCAN
1 | Hemoccult SENSA, 60–75, 3 | 1363 | 3824 | 134 | - | - | -
2 | Hemoccult SENSA, 60–75, 2 | 1647 | 4732 | 149 | | | Near-efficient
3 | Hemoccult SENSA, 50–75, 3 | 2121 | 5596 | 181 | 758 | 47 | 16.0
4 | Hemoccult SENSA, 50–75, 2 | 2584 | 7014 | 205 | 463 | 24 | 19.5
5 | Hemoccult SENSA, 50–85, 2 | 2801 | 7679 | 211 | | | Near-efficient
6 | Hemoccult SENSA, 50–75, 1 | 3350 | 9541 | 230 | 766 | 25 | 30.9
7 | Hemoccult SENSA, 50–85, 1 | 3538 | 9904 | 232 | 188 | 2 | 80.6
SimCRC
1 | Hemoccult SENSA, 60–75, 3 | 934 | 3735 | 123 | - | - | -
2 | Hemoccult SENSA, 50–75, 3 | 1587 | 5554 | 201 | 653 | 78 | 8.4
3 | Hemoccult SENSA, 50–75, 2 | 1957 | 7006 | 228 | 370 | 28 | 13.3
4 | Hemoccult SENSA, 50–75, 1 | 2654 | 9573 | 259 | 698 | 31 | 22.9
5 | Hemoccult SENSA, 50–85, 1 | 2996 | 9918 | 262 | 341 | 3 | 128.2
Fecal immunochemical test strategies
MISCAN
1 | FIT, 60–75, 3 | 1158 | 4037 | 129 | - | - | -
2 | FIT, 60–75, 2 | 1403 | 5098 | 144 | | | Near-efficient
3 | FIT, 50–75, 3 | 1769 | 6089 | 173 | 611 | 44 | 14.0
4 | FIT, 50–75, 2 | 2184 | 7916 | 198 | 415 | 25 | 16.5
5 | FIT, 50–85, 2 | 2396 | 8895 | 206 | | | Near-efficient
6 | FIT, 50–75, 1 | 2949 | 11,773 | 227 | 765 | 30 | 25.9
7 | FIT, 50–85, 1 | 3155 | 12,582 | 231 | 206 | 4 | 49.1
SimCRC
1 | FIT, 60–75, 3 | 772 | 3943 | 118 | - | - | -
2 | FIT, 50–75, 3 | 1286 | 6047 | 193 | 514 | 75 | 6.9
3 | FIT, 50–75, 2 | 1614 | 7908 | 222 | 327 | 29 | 11.3
4 | FIT, 50–75, 1 | 2295 | 11,830 | 256 | 681 | 35 | 19.7
5 | FIT, 50–85, 1 | 2623 | 12,587 | 260 | 328 | 3 | 95.7
Flexible sigmoidoscopy strategies
MISCAN
1 | FSIG, 60–75, 20 | 1047 | 917 | 114 | - | - | -
2 | FSIG, 60–75, 10 | 1311 | 1531 | 140 | | | Near-efficient
3 | FSIG, 60–75, 5 | 1491 | 2617 | 159 | | | Near-efficient
4 | FSIG, 50–75, 10 | 1685 | 2339 | 177 | | | Near-efficient
5 | FSIG, 50–75, 5 | 1911 | 4139 | 203 | 864 | 89 | 9.7
6 | FSIG, 50–85, 5 | 1996 | 4745 | 207 | 85 | 4 | 22.3
SimCRC
1 | FSIG, 60–75, 20 | 438 | 889 | 94 | - | - | -
2 | FSIG, 50–75, 20 | 662 | 1662 | 147 | 224 | 53 | 4.2
3 | FSIG, 50–85, 20 | 674 | 1661 | 147 | | | Near-efficient
4 | FSIG, 50–75, 10 | 808 | 2455 | 176 | 146 | 29 | 5.0
5 | FSIG, 50–75, 5 | 995 | 4483 | 199 | 187 | 22 | 8.4
6 | FSIG, 50–85, 5 | 1064 | 5088 | 201 | 68 | 2 | 38.5
Flexible sigmoidoscopy plus Hemoccult SENSA strategies
MISCAN
1 | FSIG + SENSA, 60–75, 20, 3 | 1817 | 4142 | 163 | --- | --- | ---
2 | FSIG + SENSA, 60–75, 10, 3 | 1933 | 4497 | 171 | | | Near-efficient
3 | FSIG + SENSA, 60–75, 5, 3 | 2031 | 5220 | 179 | 213 | 15 | 14.0
4 | FSIG + SENSA, 50–75, 20, 3 | 2658 | 6192 | 213 | | | Near-efficient
5 | FSIG + SENSA, 50–75, 10, 3 | 2756 | 6573 | 221 | | | Near-efficient
6 | FSIG + SENSA, 50–75, 5, 3 | 2870 | 7685 | 230 | 839 | 52 | 16.3
7 | FSIG + SENSA, 50–85, 5, 3 | 3042 | 8380 | 233 | 172 | 3 | 60.7
8 | FSIG + SENSA, 50–75, 5, 2 | 3142 | 8588 | 235 | 100 | 2 | 62.3
9 | FSIG + SENSA, 50–85, 10, 2 | 3245 | 8350 | 232 | | | Near-efficient
10 | FSIG + SENSA, 50–85, 5, 2 | 3321 | 9267 | 237 | 179 | 2 | 74.3
11 | FSIG + SENSA, 50–75, 20, 1 | 3558 | 9590 | 236 | | | Near-efficient
12 | FSIG + SENSA, 50–75, 10, 1 | 3591 | 9738 | 237 | | | Near-efficient
13 | FSIG + SENSA, 50–75, 5, 1 | 3635 | 10,279 | 239 | 314 | 2 | 139.8
14 | FSIG + SENSA, 50–85, 20, 1 | 3734 | 9915 | 238 | | | Near-efficient
15 | FSIG + SENSA, 50–85, 10, 1 | 3768 | 10,081 | 239 | | | Near-efficient
16 | FSIG + SENSA, 50–85, 5, 1 | 3808 | 10,611 | 240 | 172 | 1 | 154.5
SimCRC
1 | FSIG + SENSA, 60–75, 20, 3 | 956 | 7763 | 152 | - | - | ---
2 | FSIG + SENSA, 60–75, 10, 3 | 999 | 11,104 | 161 | 44 | 9 | 4.7
3 | FSIG + SENSA, 60–75, 5, 3 | 1045 | 10,064 | 169 | 45 | 8 | 5.5
4 | FSIG + SENSA, 50–75, 10, 3 | 1621 | 12,485 | 246 | | | Near-efficient
5 | FSIG + SENSA, 50–75, 5, 3 | 1655 | 11,623 | 257 | 611 | 88 | 7.0
6 | FSIG + SENSA, 50–85, 5, 3 | 1908 | 9484 | 260 | | | Near-efficient
7 | FSIG + SENSA, 50–75, 5, 2 | 1994 | 12,265 | 265 | 338 | 8 | 41.7
8 | FSIG + SENSA, 50–85, 5, 2 | 2298 | 9895 | 268 | | | Near-efficient
9 | FSIG + SENSA, 50–75, 20, 1 | 2647 | 10,214 | 270 | | | Near-efficient
10 | FSIG + SENSA, 50–75, 10, 1 | 2653 | 14,403 | 271 | | | Near-efficient
11 | FSIG + SENSA, 50–75, 5, 1 | 2666 | 13,593 | 274 | 673 | 9 | 75.7
12 | FSIG + SENSA, 50–85, 20, 1 | 2981 | 7133 | 272 | | | Near-efficient
13 | FSIG + SENSA, 50–85, 10, 1 | 2987 | 5794 | 274 | | | Near-efficient
14 | FSIG + SENSA, 50–85, 5, 1 | 2996 | 10,875 | 276 | 330 | 2 | 154.4

* COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best nonefficient strategy. Bold indicates recommendable strategy.

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Figure 2a. Colonoscopy strategies

Colonoscopies and life-years gained (compared with no screening) for a cohort of 1,000 40-year-olds for 18 colonoscopy screening strategies that vary by start age, stop age and screening interval. The solid line represents the frontier of efficient strategies.

Figure 2b. Hemoccult II strategies

Colonoscopies and life-years gained (compared with no screening) for a cohort of 1,000 40-year-olds for 18 Hemoccult II screening strategies that vary by start age, stop age and screening interval. The solid line represents the frontier of efficient strategies.

Figure 2c. Hemoccult SENSA strategies

Colonoscopies and life-years gained (compared with no screening) for a cohort of 1,000 40-year-olds for 18 Hemoccult SENSA screening strategies that vary by start age, stop age and screening interval. The solid line represents the frontier of efficient strategies.

Figure 2d. FIT strategies

Colonoscopies and life-years gained (compared with no screening) for a cohort of 1,000 40-year-olds for 18 FIT screening strategies that vary by start age, stop age and screening interval. The solid line represents the frontier of efficient strategies.

Figure 2e. Flexible sigmoidoscopy strategies

Colonoscopies and life-years gained (compared with no screening) for a cohort of 1,000 40-year-olds for 18 flexible sigmoidoscopy screening strategies that vary by start age, stop age and screening interval. The solid line represents the frontier of efficient strategies.

Figure 2f. Flexible sigmoidoscopy with Hemoccult SENSA strategies

Colonoscopies and life-years gained (compared with no screening) for a cohort of 1,000 40-year-olds for 18 colonoscopy screening strategies that vary by start age, stop age and screening interval. The solid line represents the frontier of efficient strategies.

## Age to Begin Screening

The results from the MISCAN and SimCRC models were consistent when evaluating strategies with age to begin screening of 50 or 60 years, with the start age of 50 predominating among the efficient or near efficient strategies (Table 3). However, the SimCRC model showed favorable results for the strategies in which screening begins at age 40, but these results were not corroborated by the MISCAN model (Appendix 3). To illustrate this difference, Figure 2 shows the efficient frontier with age 40 included for colonoscopy (“Frontier 40, 50, 60y”) and without age 40 (“Frontier 50, 60y”). Because the evidence for both adenoma prevalence at age 40 and the duration of the adenoma-carcinoma sequence is weak, we restricted further analysis to start ages 50 and 60.

## Age to Stop Screening

For both models and all tests, lowering the stopping age from 85 to 75 yielded small reductions in life-years gained relative to large reductions in the number of colonoscopies required (Table 3). For example, stopping screening at age 75 instead of 85 for 10-yearly colonoscopy would decrease the number of life-years gained with colonoscopy screening by 5 and 2 per 1,000 individuals for MISCAN and SimCRC, respectively, but would substantially decrease the number of colonoscopies by 398 and 358 per 1,000 individuals for MISCAN and SimCRC, respectively (Table 3). This is illustrated by the substantial reduction in the efficiency ratio for these two strategies, from 73 to 30 for MISCAN and 179 to 35 for SimCRC.

## Screening Interval

In general, strategies with longer intervals provided fewer life-years gained than strategies with shorter intervals. For all single test strategies, the currently recommended intervals of annual FOBT, 5-yearly flexible sigmoidoscopy, and 10-yearly colonoscopy provided a reasonable ratio of incremental colonoscopies per life-year gained (10 – 35) for ages 50–75 (Table 3). The results from both models showed that the current recommendation for the combination of flexible sigmoidoscopy every 5 years with a high sensitivity FOBT annually had a high efficiency ratio and that moving to a strategy of 5-yearly sigmoidoscopy with 3-yearly FOBT would minimally decrease the number of life-years gained with combination screening (by 9 and 17 per 1,000 individuals for MISCAN and SimCRC, respectively) and would substantially decrease the number of colonoscopies (by 765 and 1,011 per 1,000 individuals for MISCAN and SimCRC, respectively for ages 50–75) (Table 3). This would substantially reduce the incremental colonoscopies required for an additional life-year gained from 140 to 16 for MISCAN and from 76 to 7 for SimCRC.

## Identifying a Set of Recommendable CRC Screening Strategies

In the above analysis we found that a start age of 50 and stop age of 75 was most reasonable when considering both benefit and resource use. For that start/stop age, we first selected the colonoscopy strategy with 10-year intervals, as this has been the recommended interval; shortening the interval resulted in a marked increase in efficiency ratio (from 75 to 30 for MISCAN and 179 to 35 for SimCRC). The efficient and near-efficient strategies for start age of 50 and stop age of 75 are given in Table 4. The non-colonoscopy strategies were then chosen to have the same start/stop ages and a lower efficiency ratio, while saving similar life-years as that for colonoscopy (Table 5a). The sensitive annual FOBT strategies (Hemoccult SENSA and FIT) were comparable to 10-yearly colonoscopy in terms of life-years gained. The less-sensitive FOBT (Hemoccult II) performed annually did not have comparable effectiveness to the other FOBTs or to colonoscopy. Flexible sigmoidoscopy every 5 years, although showing a reasonable efficiency ratio, did not show comparable effectiveness to the other strategies. The combination of flexible sigmoidoscopy every 5 years with Hemoccult SENSA every 3 years had a reasonable efficiency ratio (lower than that of colonoscopy and the sensitive FOBTs) and had relatively comparable life-years gained. Had we selected the 20-year interval for colonoscopy as the comparator strategy instead of the 10-year interval, the set of strategies would include biennial screening for sensitive FOBT, annual screening for Hemoccult II, and 10-yearly screening with sigmoidoscopy in combination with 3-yearly FOBT. The life-years gained for this set of screening strategies (Table 5b) is approximately 8% to 12% lower than that shown in Table 5a.

Table 4 Efficient (or near efficient) strategies for start age of 50 and stop age of 75. The number of colonoscopies per life-year gained is calculated within screening test category

Strategy Test, Age Begin-Age Stop, Interval† | Outcomes per 1000 Persons
COL | LYG | ΔCOL | ΔLYG | ΔCOL/ΔLYG‡
MISCAN
COL, 50–75, 20 | 3325 | 203 | 1,150 | 47 | 24.7
COL, 50–75, 10 | 4136 | 230 | 811 | 27 | 29.6
COL, 50–75, 5 | 5895 | 254 | 1,362 | 18 | 74.8
SENSA®, 50–75, 3 | 2121 | 181 | 758 | 47 | 16.0
SENSA®, 50–75, 2 | 2584 | 205 | 463 | 24 | 19.5
SENSA®, 50–75, 1 | 3350 | 230 | 766 | 25 | 30.9
FIT, 50–75, 3 | 1769 | 173 | 611 | 44 | 14.0
FIT, 50–75, 2 | 2184 | 198 | 415 | 25 | 16.5
FIT, 50–75, 1 | 2949 | 227 | 765 | 30 | 25.9
Hem II®, 50–75, 3 | 1033 | 121 | | | Near efficient
Hem II®, 50–75, 2 | 1335 | 149 | 482 | 44 | 11.0
Hem II®, 50–75, 1 | 1982 | 194 | 647 | 45 | 14.3
Fsig, 50–75, 10 | 1685 | 177 | | | Near efficient
Fsig, 50–75, 5 | 1911 | 203 | 864 | 89 | 9.7
FsigSENSA®, 50–75, 20,3 | 2658 | 213 | | | Near efficient
FsigSENSA®, 50–75, 10,3 | 2756 | 221 | | | Near efficient
FsigSENSA®, 50–75, 5,3 | 2870 | 230 | 839 | 52 | 16.3
FsigSENSA®, 50–75, 5,2 | 3142 | 235 | 100 | 2 | 62.3
FsigSENSA®, 50–75, 20,1 | 3558 | 236 | | | Near efficient
FsigSENSA®, 50–75, 10,1 | 3591 | 237 | | | Near efficient
FsigSENSA®, 50–75, 5,1 | 3635 | 239 | 314 | 2 | 139.8
SimCRC
COL, 50–75, 20 | 2885 | 246 | 1,106 | 82 | 13.5
COL, 50–75, 10 | 3756 | 271 | 871 | 25 | 34.7
COL, 50–75, 5 | 5572 | 282 | 1,816 | 10 | 178.8
SENSA®, 50–75,3 | 1587 | 201 | 653 | 78 | 8.4
SENSA®, 50–75,2 | 1957 | 228 | 370 | 28 | 13.3
SENSA®, 50–75,1 | 2654 | 259 | 698 | 31 | 22.9
FIT, 50–75,3 | 1286 | 193 | 514 | 75 | 6.9
FIT, 50–75,2 | 1614 | 222 | 327 | 29 | 11.3
FIT, 50–75,1 | 2295 | 256 | 681 | 35 | 19.7
Hem II®, 50–75,3 | 699 | 129 | 275 | 54 | 5.1
Hem II®, 50–75, 2 | 921 | 162 | 221 | 33 | 6.7
Hem II®, 50–75, 1 | 1456 | 218 | 536 | 56 | 9.6
Fsig, 50–75, 20 | 662 | 147 | 224 | 53 | 4.2
Fsig, 50–75, 10 | 808 | 176 | 146 | 29 | 5.0
Fsig, 50–75, 5 | 995 | 199 | 187 | 22 | 8.4
FsigSENSA®, 50–75, 10,3 | 1621 | 246 | | | Near efficient
FsigSENSA®, 50–75, 5,3 | 1655 | 257 | 611 | 88 | 7.0
FsigSENSA®, 50–75, 5,2 | 1994 | 265 | 338 | 8 | 41.7
FsigSENSA®, 50–75, 20,1 | 2647 | 270 | | | Near efficient
FsigSENSA®, 50–75, 10,1 | 2653 | 271 | | | Near efficient
FsigSENSA®, 50–75, 5,1 | 2666 | 274 | 673 | 9 | 75.7

* COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA; ΔCOL = incremental number of colonoscopies compared with the next-best non-efficient strategy; ΔLYG = incremental number of life-years gained compared with the next-best nonefficient strategy. Bold indicates recommendable strategy

† Age and intervals expressed as years.

‡ Near-efficient strategies yield life-years gained within 98% of the efficient frontier.

Table 5a Outcomes for the Recommendable Set of Efficient Screening Strategies Using Colonoscopy beginning at age 50, Stopping at age 75, and 10 year Interval as Starting Strategy

Strategy Test, Age Begin-Age Stop, Interval* | Outcomes per 1000 Persons
COL | Non-COL Tests | LYG | Efficiency ratio† | Incidence Reduction (%) | Mortality Reduction (%)
MISCAN
COL, 50–75, 10 | 4136 | 0 | 230 | 29.6 | 51.9 | 64.6
Hemoccult SENSA, 50–75, 1 | 3350 | 9541 | 230 | 30.9 | 49.7 | 66.0
FIT, 50–75, 1 | 2949 | 11,773 | 227 | 25.9 | 47.2 | 64.6
Hemoccult II, 50–75, 1 | 1982 | 16,232 | 194 | 14.3 | 37.1 | 55.3
FSIG, 50–75, 5 | 1911 | 4139 | 203 | 9.7 | 46.8 | 58.5
FSIG + SENSA, 50–75, 5, 3 | 2870 | 7685 | 230 | 16.3 | 51.2 | 65.7
SimCRC
COL, 50–75, 10 | 3756 | 0 | 271 | 34.7 | 80.6 | 84.4
Hemoccult SENSA, 50–75, 1 | 2654 | 9573 | 259 | 22.9 | 73.2 | 81.2
FIT, 50–75, 1 | 2295 | 11,830 | 256 | 19.7 | 70.8 | 80.0
Hemoccult II, 50–75, 1 | 1456 | 16,239 | 218 | 9.6 | 56.6 | 69.0
FSIG, 50–75, 5 | 995 | 4483 | 199 | 8.4 | 59.0 | 62.2
FSIG + SENSA, 50–75, 5, 3 | 1655 | 11,623 | 257 | 7.0 | 72.2 | 79.3

COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

† Efficiency ratio corresponds with ΔCOL/ΔLYG in the Appendix 2 Tables and represents the relative burden per unit of benefit achieved.

Table 5b Secondary Outcomes for the Recommendable Set of Efficient Screening Strategies Using Colonoscopy beginning at age 50, Stopping at age 75, and 20 Year Interval as Starting Strategy

Strategy Test, Age Begin-Age Stop, Interval* | Outcomes per 1000 Persons
COL | Non-COL Tests | LYG | Efficiency ratio† | Incidence Reduction (%) | Mortality Reduction (%)
MISCAN
COL, 50–75, 20 | 3325 | 0 | 203 | 24.7 | 46.6 | 58.8
Hemoccult SENSA, 50–75, 3 | 2121 | 5596 | 181 | 16.0 | 35.9 | 52.8
FIT, 50–75, 2 | 2184 | 7916 | 198 | 16.5 | 38.2 | 56.2
Hemoccult II, 50–75, 1 | 1982 | 16,232 | 194 | 14.3 | 37.1 | 55.3
FSIG, 50–75, 5 | 1911 | 4139 | 203 | 9.7 | 46.8 | 58.5
FSIG + SENSA, 50–75, 10, 3 | 2756 | 6573 | 221 | 17.2‡ | 48.3 | 63.1
SimCRC
COL, 50–75, 20 | 2885 | 0 | 246 | 13.5 | 72.6 | 77.3
Hemoccult SENSA, 50–75, 2 | 1957 | 7006 | 228 | 13.3 | 61.4 | 72.5
FIT, 50–75, 2 | 1614 | 7908 | 222 | 11.3 | 57.4 | 69.9
Hemoccult II, 50–75, 1 | 1456 | 16,239 | 218 | 9.6 | 56.6 | 69.0
FSIG, 50–75, 5 | 995 | 4483 | 199 | 8.4 | 59.0 | 62.2
FSIG + SENSA, 50–75, 10, 3 | 1621 | 12,485 | 246 | 7.4‡ | 80.6 | 88.3

COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

† Efficiency ratio corresponds with ΔCOL/ΔLYG in the Appendix 2 Tables and represents the relative burden per unit of benefit achieved.

‡ Near efficient strategy; efficiency ratio represents ratio relative to next least effective non-dominated strategy.

## Sensitivity Analysis

Our overall conclusions did not change with variations in test characteristics. As expected, results for the worst-case analysis showed lower life-years gained than the base case, and the best-case analysis had greater life-years gained. For strategies that remained on the efficient frontier, the incremental number of colonoscopies per life-year gained was typically greater than the base-case value with the best-case assumption, and lower with the worst-case assumption.

Figure 3 shows the expected number of colonoscopies and life-years gained for over adherence of 50%, 80% and 100% for the recommended strategies shown in Table 6. When adherence was relatively high at 80%, the colonoscopy strategy (i.e., 10-yearly screening from aged 50 to 75) was the most effective in term of life-years gained and Hemoccult SENSA, FIT and the combination strategies all provided life-years gained within 8% of that of the colonoscopy strategy. When overall adherence was only 50%, the colonoscopy strategy was no longer the most effective and Hemoccult SENSA, FIT, and the combination strategies had life-years gained higher or equivalent to that of the colonoscopy strategy. Annual Hemoccult II and flexible sigmoidoscopy every five years remained the two least attractive alternatives in terms of life-years gained across different adherence levels.

Table 6 Subset of strategies for start age of 50 and stop age of 75 varied by overall adherence to screening (see Figure 3)

Strategy Test, Age Begin-Age Stop, Interval* | Outcomes per 1000 Persons
| 50% adherence | | 80% adherence | | 100% adherence
| COL | LYG | COL | LYG | COL | LYG
MISCAN
COL, 50–75, 10 | 2250 | 140 | 3193 | 184 | 4136 | 230
SENSA®, 50–75, 1 | 1960 | 156 | 2405 | 176 | 3350 | 230
FIT, 50–75, 1 | 1670 | 151 | 2099 | 173 | 2949 | 227
Hem II®, 50–75, 1 | 1041 | 117 | 1386 | 145 | 1982 | 194
Fsig, 50–75, 5 | 1150 | 128 | 1369 | 155 | 1911 | 203
FsigSENSA®, 50–75, 5,3 | 1674 | 153 | 2050 | 177 | 2870 | 230
SimCRC
COL, 50–75, 10 | 1977 | 168 | 2904 | 227 | 3756 | 271
SENSA®, 50–75, 1 | 1361 | 182 | 1920 | 217 | 2654 | 259
FIT, 50–75, 1 | 1140 | 177 | 1629 | 213 | 2295 | 256
Hem II®, 50–75, 1 | 666 | 130 | 993 | 172 | 1456 | 218
Fsig, 50–75, 5 | 544 | 122 | 711 | 158 | 995 | 199
FsigSENSA®, 50–75, 5,3 | 770 | 168 | 1153 | 210 | 1655 | 257

COL = colonoscopy; FSIG = flexible sigmoidoscopy; LYG = life-years gained compared with no screening; SENSA = Hemoccult SENSA

* Age and intervals expressed as years.

Figure 3. Sensitivity analysis of adherence

Colonoscopies and life-years gained by adherence level for the recommendable set of screening strategies. SENSA = Hemoccult SENSA; FIT = fecal immunochemical test; FSIG = flexible sigmoidoscopy