# Methods

We used two microsimulation models, MISCAN (MI-crosimulation Screening ANalysis) (12–14) and SimCRC (Simulation Model of Colorectal Cancer) (15), to estimate the life-years gained relative to no screening and the colonoscopies required (i.e., an indicator for resource use and risk of complications) for different CRC screening strategies defined by test, age to begin screening, age to stop screening, and screening interval. We aimed to identify a set of recommendable strategies with comparable clinical benefit and an efficient use of colonoscopy resources. Using two models (i.e., a comparative modeling approach) adds credibility to the results and serves as a sensitivity analysis on the underlying structural assumptions of the models, particularly pertaining to the unobservable natural history of CRC.

## Microsimulation Models

A detailed description of the MISCAN and SimCRC models can be found in Appendix 1. Standardized model profiles are available online (http://cisnet.cancer.gov/profiles/), which provide a detailed description of the underlying parameters of the natural history for each model to provide transparency of the models. In brief, both models simulate the life histories of a large population of individuals from birth to death. As each individual ages, there is a chance that an adenoma develops. One or more adenomas can occur in an individual and each can independently develop into preclinical (i.e., undiagnosed) CRC (Figure 1). The risk of developing an adenoma depends on age, sex, and baseline individual risk. The models track the location and size of each adenoma, these characteristics influence disease progression and the chance the adenoma is found by screening. Adenomas can progress from small (≤ 5 mm) to medium (6–9 mm) to large (≥ 10 mm) size. Some adenomas eventually become malignant, transforming to stage I preclinical cancer. A preclinical cancer has a chance of progressing through stages I to IV, and may be diagnosed by symptoms at any stage. Survivorship after diagnosis depends on the stage of disease.

Figure 1. Graphical representation of natural history of disease as modeled by MISCAN and SimCRC models

The opportunity to intervene in the natural history through screening is noted. Screening can either remove a precancerous lesion (i.e., adenoma), thus moving a person to the “No lesion” state, or through early detection, which makes an undiagnosed cancer clinically detected at a potentially earlier stage of disease where it is more amenable to treatment.

The natural history component of each model was calibrated to 1975-1979 United States clinical incidence data (16) and adenoma prevalence from autopsy studies in the same period (17–26). We used this period because incidence rates and adenoma prevalence had not yet been affected by screening. We adjusted the adenoma prevalence from studies of non-US populations to that of the United States using standardized CRC incidence ratios. The models use all-cause mortality estimates from the US life tables and stage-specific CRC survival data from 1996-1999 SEER) (16). A comparison of outcomes from the natural history components of the models is shown in Table 1.

Table 1 Comparison of the Natural History Outcomes from the MISCAN and SimCRC Models

| MISCAN, by Age | | | SimCRC, by Age
Outcome | 40y | 50y | 60y | 40y | 50y | 60y
Adenoma prevalence | 10.9% | 28.7% | 36.7% | 10.2% | 18.3% | 29.5%
Size distribution of adenomas
≤ 5 mm | 60.9% | 64.8% | 52.6% | 59.3% | 53.9% | 51.1%
6–9 mm | 20.9% | 19.0% | 25.3% | 31.6% | 34.4% | 35.8%
≥ 10 mm | 18.2% | 16.2% | 22.1% | 9.1% | 11.7% | 13.0%
Location of adenomas
Proximal | 34.3% | 34.3% | 34.3% | 62.0% | 62.4% | 62.8%
Distal | 34.5% | 34.5% | 34.5% | 30.5% | 30.4% | 30.3%
Rectum | 31.2% | 31.2% | 31.2% | 7.5% | 7.2% | 6.8%
Cumulative CRC incidence
10-year | 0.2% | 0.7% | 1.6% | 0.2% | 0.7% | 1.4%
20-year | 0.9% | 2.3% | 4.0% | 0.9% | 2.1% | 3.4%
Lifetime | 7.3% | 7.1% | 6.4% | 6.2% | 5.9% | 5.3%
Stage distribution of CRC cases
Stage I | 16.6% | 21.1% | 19.3% | 24.0% | 21.9% | 19.4%
Stage II | 23.0% | 28.3% | 31.4% | 39.6% | 35.1% | 34.8%
Stage III | 33.7% | 26.3% | 26.1% | 20.0% | 22.2% | 22.6%
Stage IV | 26.7% | 24.4% | 23.2% | 16.4% | 20.7% | 23.2%

CRC = colorectal cancer

* Because of rounding, not all percentages age to 100%.

The effectiveness of a screening strategy is modeled through a test's ability to detect lesions (i.e., adenomas, preclinical cancer) which can be removed. Once screening is introduced, a simulated person who has an underlying lesion has a chance of having it detected during a screening round depending on the sensitivity of the test for that lesion and whether the lesion is within the reach of the test. Screened persons without an underlying lesion can have a false-positive test result and undergo an unnecessary follow-up colonoscopy. Hyperplastic polyps are not modeled explicitly but their detection is reflected in the specificity of the screening tests. The models incorporate the risk of fatal complications associated with perforation during colonoscopy. Both models have been validated against the long-term reductions in CRC mortality and CRC incidence with annual FOBT reported in the Minnesota Colon Cancer Control Study (3, 27, 28) and show good concordance with the trial results.

## CRC Screening Strategies

In consultation with the USPSTF, we included the following basic strategies: (1) no screening, (2) colonoscopy, (3) FOBT (Hemoccult II, Hemoccult SENSA, or fecal immunochemical test (FIT)), (4) flexible sigmoidoscopy (with biopsy), and (5) flexible sigmoidoscopy combined with Hemoccult SENSA. Payments by the Centers for Medicare and Medicaid Services for the tests are $4.54 for a guaiac based test (either Hemoccult II or Hemoccult SENSA); $22.22 for a fecal immunochemcial test; $161 and $348 for flexible sigmoidoscopy without and with biopsy with pathology evaluation; and $498 and $649 for colonoscopy without and with polypectomy and pathology evaluation (29). The intent of this analysis was to use the number of colonoscopies required per strategy as an indicator of resources and risks required. These payment estimates (reflecting approximately 80% of the allowable charges) serve as a relative indication of resource allocation but are not intended to be used as a direct comparison of the tests and the effect of the screening strategy.

For each basic strategy we evaluated start ages of 40, 50, and 60 years, and stop ages of 75 and 85 years. For the FOBT strategies we considered screening intervals of 1, 2, and 3 years, and for the sigmoidoscopy and colonoscopy strategies we considered intervals of 5, 10, and 20 years. These variations resulted in 145 strategies: 90 single-test strategies, 54 combination-test strategies, and one no-screening strategy. The stop age reflects the oldest possible age to screen but the actual stopping age is dictated by the start age and screening interval.

In the base case, we assumed 100% adherence for screening tests, follow-up of positive findings, and surveillance of individuals found to have adenomas. Individuals with a positive FOBT or with an adenoma detected by sigmoidoscopy were referred for a follow-up colonoscopy. For years in which both tests were due for the combined strategy, the FOBT was performed first and if positive, the patient was referred for a follow-up colonoscopy. In those years, flexible sigmoidoscopy was done only for those with a negative FOBT. If the follow-up colonoscopy was negative, then the individual was assumed to undergo subsequent screening with colonoscopy with a 10-year interval (as long as the repeat colonoscopy was negative) and did not return to the initial screening schedule, as is the recommendation of the US Multi-Society Task Force and American Cancer Society (7, 30). All individuals with an adenoma detected were followed with colonoscopy surveillance per the Multi-Society guidelines (30, 31). The surveillance interval depended upon the number and size of the adenomas detected on the last colonoscopy, ranging from 3 to 5 years and was assumed to continue for the remainder of the person's lifetime.

We estimated the CRC screening test characteristics from a review of the available literature (Table 2) (29). The test characteristics for FIT were based on an update of the literature review in the AHRQ-CMS report on FIT (32). The FIT estimates in this report were updated based on a large study (33) on sensitivity and specificity of FIT published after the FIT AHRQ-CMS report(32). The results of the Morikawa study were similar to the estimates of sensitivity and specificity for CRC used in the previous report on FIT to AHRQ-CMS (32). Consequently the same estimates for the FIT's specificity and sensitivity for CRC were retained from the previous report. However we slightly increased the sensitivity estimates for adenomas for FIT compared to the estimates of the 2003 FIT Report (32). Test characteristics of Hemoccult SENSA were assumed to be similar to that of FIT. Lack of specificity was assumed to be higher for Hemoccult SENSA, resulting in slightly higher sensitivity for adenomas for SENSA compared to FIT. The estimated CRC sensitivity of Hemoccult II was not changed from the 40% estimated in the 2003 FIT report. Sensitivities for adenomas were estimated by assuming the same ratio between adenoma sensitivity and CRC sensitivity as for FIT.

Table 2 Test Characteristics used in the MISCAN and SimCRC Models

| | Sensitivity Analysis
Test Characteristic | Base-Case Value | Best-Case Value | Worst-Case Value
Hemoccult II
Specificity | 98.0% | 99.0% | 95.0%
Sensitivity adenomas ≤ 5 mm* | 2.0% | 1.0% | 5.0%
Sensitivity adenomas 6–9 mm | 5.0% | 13.7% | 5.0%
Sensitivity adenomas ≥ 10 mm | 12.0% | 27.5% | 8.9%
Sensitivity cancers | 40.0% | 50.0% | 25.0%
Reach | Whole colorectum | Not varied | Not varied
Mortality rate | 0 | Not varied | Not varied
Hemoccult SENSA
Specificity | 92.5% | 95.0% | 90.0%
Sensitivity adenomas ≤ 5 mm* | 7.5% | 5.0% | 10.0%
Sensitivity adenomas 6–9 mm | 12.4% | 26.2% | 10.0%
Sensitivity adenomas ≥ 10 mm | 23.9% | 49.4% | 17.7%
Sensitivity cancers | 70.0% | 87.0% | 50.0%
Reach | Whole colorectum | Not varied | Not varied
Mortality rate | 0 | Not varied | Not varied
Fecal immunochemical test
Specificity | 95.0% | 98.0% | 92.5%
Sensitivity adenomas ≤ 5 mm* | 5.0% | 2.0% | 7.5%
Sensitivity adenomas 6–9 mm | 10.1% | 24.0% | 7.5%
Sensitivity adenomas ≥ 10 mm | 22.0% | 48.0% | 16.0%
Sensitivity cancers | 70.0% | 87.0% | 50.0%
Reach | Whole colorectum | Not varied | Not varied
Mortality rate | 0 | Not varied | Not varied
Sigmoidoscopy (within reach)
Specificity | 92.0% | Not varied | Not varied
Sensitivity adenomas ≤ 5 mm | 75.0% | 79.0% | 70.0%
Sensitivity adenomas 6–9 mm | 85.0% | 92.0% | 80.0%
Sensitivity adenomas ≥ 10 mm | 95.0% | 99.0% | 92.0%
Sensitivity cancers† | 95.0% | 99.0% | 92.0%
Reach | 80% to sigmoid-descending junction, 40% to splenic flexure | 100% to sigmoid-descending junction, 80% to splenic flexure | 60% to sigmoid-descending junction, 30% to splenic flexure
Mortality rate | 0 | Not varied | Not varied
Colonoscopy (within reach)
Specificity | 90.0% | Not varied | Not varied
Sensitivity adenomas ≤ 5 mm | 75.0% | 79.0% | 70.0%
Sensitivity adenomas 6–9 mm | 85.0% | 92.0% | 80.0%
Sensitivity adenomas ≥ 10 mm | 95.0% | 99.0% | 92.0%
Sensitivity cancers | 95.0% | 99.0% | 92.0%
Reach | 95% to end of cecum; remaining 5% between rectum and cecum | Not varied | Not varied
Mortality rate | 1 per 10,000 | Not varied | Not varied

* We assume small adenomas do not bleed and cannot be detected by fecal occult blood tests (FOBTs). The sensitivity of FOBTs for adenomas ≤ 5 mm is based on the false positive rate (i.e., 1 - specificity).

† The sensitivity of sigmoidoscopy for colorectal cancer over the whole colorectum is 72% with MISCAN and 61% with SimCRC.

Sensitivity estimates for colonoscopy were based on a recent meta-analysis (34). We assumed the same sensitivity for sigmoidoscopy within the reach of the scope.

Our review was conducted independently of the systematic evidence review conducted for the USPSTF (9, 10) and parallel in time.

## Evaluation of Outcomes

### 1) Determination of efficient strategies

The most effective strategy was defined as the one with the greatest life-years gained relative to no screening. However, it is important to consider the relative intensity of test use required to achieve those gains. The more effective strategies tended to be associated with more colonoscopies on average in a person's lifetime, which translated into an increased risk of colonoscopy-related complications. We used an approach that mirrors that of cost-effectiveness analysis (35) to identify the set of efficient, or dominant, strategies within each test category. A strategy was considered dominant when there was no other strategy or combination of strategies that provided more life-years with the same number of colonoscopies. We conducted this analysis separately for each of the five basic screening strategies because the number of non-colonoscopy tests differed by strategy. We then ranked the efficient screening strategies by increasing effectiveness and calculated the incremental number of colonoscopies (ΔCOL) per 1000, the incremental life-years gained (ΔLYG) per 1000 and the incremental number of colonoscopies necessary to achieve a year of life (ΔCOL/ΔLYG) relative to the next less effective strategy, which we refer to as the “efficiency ratio.” The line connecting the set of efficient strategies is called the (efficient) frontier. We also identified “near efficient” strategies—strategies that yielded life-years gained within 98% of the efficient frontier.

### 2) Determination of recommendable strategies at certain level of effectiveness

We further only considered efficient or near-efficient strategies. We assumed that the set of recommendable strategies would all have the same start and stop age, because recommending different start/stop ages by test may be confusing for patients and practitioners. We looked at the incremental number of colonoscopies relative to the life-years gained to determine what would be reasonable start and stop ages. For a given start/stop age we selected a colonoscopy strategy, with the default being the generally recommended 10-year screening interval. From the other test categories we selected strategies with the most comparable screening effectiveness to colonoscopy, and with a lower efficiency ratio than that for colonoscopy. This was because strategies that have more intensive use of tests other than colonoscopy should have a lower efficiency ratio than strategies with less intensive (or no) use of non-colonoscopy tests (i.e., this ratio would be higher if other tests were included in the numerator). Alternative sets of recommendable CRC screening strategies were obtained with different colonoscopy strategies selected as the initial comparator.

## Sensitivity Analyses

The primary sensitivity analysis was the comparison of findings across two independently-developed microsimulation models. We also performed sensitivity analyses on test characteristics, where we used all of the least-favorable values in a worst-case analysis and all of the most favorable values in a best-case analysis (Table 2). For colonoscopy and sigmoidoscopy, we used the confidence intervals reported in the meta-analysis by van Rijn (34) as the range tested. For FOBT, we used the ranges reported in the literature (9, 10, 29).

To assess the relative impact of decreased adherence, we explored the impact of overall adherence rates of 50% and 80%. We incorporated correlation of screening behavior within an individual by assuming that the population is comprised of four groups: those who are never screened and those with low, moderate, and high adherence, with 10% of the population in the never screened group and 30% in each of the other groups. For the overall 80% adherence assumption, each time a person is scheduled for a screen there is a 0%, 78%, 89%, and 100% chance that s/he has the test done if in the non-adherent, low, moderate, and high adherence group respectively. For an overall 50% adherence assumption, each time a person is schedule for a screen there is a 0%, 39%, 56%, and 72% chance that s/he has the test done if in the non-adherent, low, moderate, and high adherence group respectively. For both overall screening adherence assumptions (i.e., 50% and 80%) we assumed that adherence with follow-up and surveillance was 75%, 85%, and 95% for those with low, moderate, and high adherence, respectively. We assumed that individuals remain in their screening behavior group.

## Role of the Funding Source

NCI supported the infrastructure for the CISNET models. The Agency for Healthcare Research and Quality funded this work and provided project oversight and review. The authors worked with four USPSTF members to specify the overall questions, select the strategies, and resolve methodological issues during the conduct of the review. The draft decision analysis was reviewed by three external peer reviewers (listed in the acknowledgements) and revised for the final version. The authors have sole responsibility for the models and model results.

## Institutional Review Board

This research did not include patient-specific information and was exempt from IRB review (exemption 4).