# Appendixes

Appendix A. Detailed Methods

Appendix B. Key Question 1 study details

Appendix C. Study Details KQ2a

Appendix D. Study Details KQ2B. CT Colonography, Fecal Occult Blood Tests, and Fecal DNA

Appendix E. Study Details. KQ3a Harms of colonoscopy and flexible sigmoidoscopy

Appendix F. Study Details KQ3b Harms of CT colonography

Appendix G. Colorectal cancer screening studies awaiting assessment