# Appendix G. Colorectal cancer screening studies awaiting assessment

Study/Trial Name | Country | Main Study Question(s) | Study Design | Population Addressed | Status
Flexible Sigmoidoscopy
SCORE- Italian Sig. Screening (parallel to UK Flex Sig study) | Italy | Estimate the impact of this strategy on CRC incidence and mortality and the duration of the protective effect. | Multicenter RCT | Ages 55–64 Random sample drawn from NHS registry, population based screening population | Baseline findings published. Final results not published as of 3/2008
PLCO Cancer Screening Trial | US | Determine if screening with flexible sigmoidoscopy q5 years can reduce mortality from CRC. | Multicenter RCT | Ages 55–74, screening population | Enrollment closed 2001, screening until 2006. Additional follow-up for 10 yrs. Final results not published as of 3/2008
UK/MRC/NHS R&D ‘once only’ flexible sigmoidoscopy UK Flexible Sigmoidoscopy Screening Trial (UKFSST) | UK | Determine if single flexible sigmoidoscopy screening offered at around age 60 can lower the incidence and mortality of CRC. | Multicenter RCT, with longterm registry followup | Ages 55–64, screening population | Flexible sigmoidoscopy completed in 1999 Final results not published as of 3/2008
Norwegian CRC Prevention Trial (NORCCAPS) | Norway | Determine if screening with flexible sigmoidoscopy or flexible sigmoidoscopy and FOBT can reduce mortality and morbidity of CRC. | RCT | Ages 50–64 Population based screen population | Completed (1999-2001 w/ 5 yr follow-up), results from the 5 year followup expected in 2007 Final results not published as of 3/2008
Colonoscopy studies
Colonoscopy or FOBT in Screening Healthy Participants for Colorectal Cancer #NCT00102011 | US | Determine how well colonoscopy works compared to FOBT in screening health participants for colorectal cancer. | Multicenter RCT | Ages 50–69, average risk | Currently recruiting patients No new publications as of 3/2008
National Polyp Study | US | Assess surveillance strategies in patients after removal of newly diagnosed adenomas. | Multicenter RCT | Persons with removal of one or more adenomas | Completed No new publications as of 3/2008
Japan Polyp Study | Japan | Evaluate the follow-up surveillance strategies in patients who have undergone colonoscopies for the control of colorectal cancer (removal of polyps by high resolution chromoendooscopy). | Multicenter RCT | Ages 40–69, previously average risk prior to initial colonoscopies | Began 2000, assumed to be ongoing No new publications as of 3/2008
A Follow-up Colonoscopy Examination in Patients who had Previously Undergone Screening Colonoscopy | China | Determine the prevalence of colonic neoplasm in patients who had previously undergone screening colonoscopy; and to determine the optimal time interval for re-screening in average risk individuals. | Prospective cohort | Ages 50–70, previously asymptomatic prior to initial colonoscopy; participants from prior screening colonoscopy trials [Sung Gastroenterology 2003; Leung, JG 2004] | Ongoing No new publications as of 3/2008
Pooling project on followup colonoscopies Primary author: Elena Martinez | US (assumed) | Assess followup lesions in surveillance colonoscopies. | 8 Pooled prospective (assumed) cohorts | Unknown | Manuscript is currently in submission
Complications of colonoscopy from CORI | US | Assess 30d complications of colonoscopy using CORI dataset | Prospective (assumed) cohort | Unknown | Manuscript is currently in submission
Adverse events following routine colonoscopy in the Medicare population | US | Determine rates of adverse events following routine colonoscopy in a population based cohort of Medicare beneficiaries | Case-control analyses | Random sample of Medicare beneficiaries at average risk for colorectal cancer | Abstract presented No new publications as of 3/2008
Fecal Tests
Screening tests in Detecting Colorectal Cancer Study PI: David Ahlquist | US | Compare the performance characteristics (sensitivity, specificity, and predictive values) of fecal occult blood (FOB) testing and multitarget DNA-based assay panel (MTAP) testing applied to stools and plasma in identifying colorectal cancer. Compare the detection rates of colorectal neoplasia using MTAP alone, flexible sigmoidoscopy alone, and combination sigmoidoscopy and FOB testing. | RCT | Average risk for CRC | Ongoing No new publications as of 3/2008
CT Colonography
National CT Colonography Trial (ACRIN) #NCT00084929 | US | Compare the sensitivity of CTC vs colonoscopy for detecting lesions in asymptomatic participants. Also will address interobserver variation, effect of colonic preparations, patient acceptance, and cost. | Multicenter RCT | Age 50 years and older, asymptomatic persons | Ongoing Abstract of initial findings presented, manuscript in submission
Munich Colorectal Cancer Prevention Trial | Germany | Compare colonoscopy, CTC, flexible sigmoidoscopy, and blood tests such as fecal occult blood test (FOBT) and imHb immunochemical fecal occult blood testing (FIT), and also combinations of blood testing (FOBT, FIT) and sigmoidoscopy, in their detection of neoplastic lesions 6 mm and 10 mm and larger. | Prospective cohort | Age 50 years and older, screening population | Abstract presented No new publications as of 3/2008
Virtual Colonoscopy for Primary Colorectal Screening | US | Determine if CTC screening and surveillance of sub-cm polyps is safe and effective | Prospective case-control | 50 yrs and older, screening population | Article in press
Clinical and economic impact of unsuspected extracolonic findings at screening CTC | US | Evaluate frequency and estimated costs of additional diagnostic workup for extracolonic findings detected at CTC screening | Prospective cohort | Asymptomatic adults undergoing CTC screening | Manuscript in submission