# Appendix F. Study Details KQ3b Harms of CT colonography

CT colonography. We found five fair quality cohort studies that addressed potential adverse effects of screening CT colonography. (see Appendix F Table 1)

Kim and colleagues reported their findings from a fair quality, prospective cohort of 3120 CT colonographies conducted in a predominantly average risk, asymptomatic population at a US university based medical center. ^182^ Their cohort was 56 percent women with a mean age of 57 years old. It is unclear the duration of follow-up for adverse events. They found no clinically significant adverse events from CT colonography.

Pickhardt and colleagues presented their findings from a fair quality study of 16 medical centers from five countries participating in the Working Group on Virtual Colonoscopy. ^190,^ ^228^ Their retrospective cohort included 21,923 studies, of which 11,707 were screening CT colonographies for average risk, asymptomatic persons. Each center conducted chart reviews to identify clinically significant adverse events requiring hospitalization, follow-up at each center was variable, generally up to 30 days. They found an overall perforation rate of 0.009 percent (2/21,923), symptomatic perforation rate of 0.0045 percent (1/21,923); however none of the perforations were in the screening subgroup. They also reported on other clinically significant adverse events, which included exacerbation of renal failure in 0.009 percent (2/21,923) persons, and chest pain (without myocardial infarction) in 0.0045 percent (1/21,923) persons.

Sosna and colleagues reported their findings from a fair quality retrospective chart review of all CT colonographies conducted over a 48 month period in 11 imaging centers in Israel. ^191^ Their cohort included 11,870 studies, for both screening and diagnostic purposes, breakdown by indication is not reported. Their cohort was 42 percent women, ages 38 to 90 years, with an average age of 60 years. They found an overall perforation rate of 0.06 percent (7/11,870), however only one of these perforations was in the screening subgroup. It is unclear how many of these cases were symptomatic, though four of the seven cases required surgical intervention. The perforation rate for those in the screening subgroup cannot be calculated because the breakdown of studies by indication is not reported. It is unclear if they collected additional information on other clinically significant adverse events.

Edwards and colleagues reported their findings from a small, fair quality, prospective cohort of 340 CT colongraphies conducted in an average risk, asymptomatic population in Australia. ^189^ Their cohort was 49 percent women, ages 50 to 54 and 65 to 69 years old. It is unclear the duration of follow-up for adverse events. They found no clinically significant adverse events from CT colonography. They reported 3 syncopal events associated with the magnesium citrate/sodium picosulphate (SPS) bowel preparation which was discontinued and replaced with a polyethylene glycol (PEG)/SPS bowel prep.

Pickhardt and colleagues reported their findings from a fair quality, prospective cohort of 1247 CT colonographies conducted in an average risk, asymptomatic population in three US medical centers. ^136,^ ^189^ Their cohort was 41 percent women, ages 40 to 79 years, with an average age of 58 years old. It is unclear the duration of follow-up for adverse events. They found no clinically significant adverse events from CT colonography.

Radiation exposure. Jensch and colleagues systematically searched PubMed from 1996 to 2004 for studies investigating CT Colonography. ^192^ They found 36 institutions published 74 studies, and contacted each research institution for their current scan protocol. Twenty-eight of the 36 institutions provided their current protocol, and estimates of effective radiation dose were then calculated with the IMPACT Patient Dosimetry Calculator. In 2004, they found a median dose of 10.2mSv, with a range of radiation doses of 2.4 to 23.4mSv per two positions, both supine and prone. From 1998 to 2004 the range of radiation doses was 1.2mSv to 23.4mSv. The range of radiation doses from 1998 to 2004 did not vary significantly even though use of multi-detector CT scanners (MDCT) increased over time from 17 percent in 1999 to 96 percent of institutions in 2004.

VanGelder and colleagues systematically searched Medline from 1997 to 2001 for English language articles that addressed diagnostic accuracy of CT colonography and supplied the required specifications to calculate effective radiation dose. ^193^ In addition, scan parameter information was updated by contacting authors and additional investigators who were known to perform research on the diagnostic accuracy of CT colonography who were present at the Second International Symposium on Virtual Colonoscopy in 2000. Effective radiation doses were calculated with the IMPACT patient Dosimetry Calculator. They included the scan protocols from 13 centers that performed research CT colonography in 2002. They found a median dose of 8.8mSv, with a range of radiation doses from approximately four to 18mSv for dual positioning, both supine and prone.

Table 1 Evidence table key question 3B

Reference | Setting/Study Design | Screening test operator characteristics | Patient Characteristics: | Inclusion/ Exclusion Criteria | Procedure | Perforation | Radiation dose | Other adverse effects | Applicability
CT Colonography
Kim 2007 ^182^ | Prospective Cohort Single institution, US recruitment through referrals for screening colonoscopy | 5 gastroradiologists experienced in CTC | Age, mean: 57.0 yr % female: 56 % ethnic origin: NR SES: NR % symptomatic: 2 | Inclusion: PCP referral for CRC screening Exclusions: polyp surveillance, history of bowel disorder (e.g., inflammatory bowel disease, the polyposis syndrome, HNPCC) | Total CT Colonoscopies: 3120 | Total Perforations: 0/3120 (0%) No perforations from 246 (7.9%) followup therapeutic OC | NR | Total Perforations: 0/3120 (0%) No other adverse effects from 246 (7.9%) followup therapeutic OC | Fair
Pickhardt 2006 ^190^ Fair | International (5 countries), 16 medical centers part of the Working Group on Virtual Colonoscopy All CTC conducted Retrospective Cohort | Operator: ‘experienced’ radiologists; direct physician monitoring of CTC in 45.8% of cases Experience: at 11/16 center more than 1000 CTC performed | Age: NR % female: NR % ethnic origin: NR SES: NR % symptomatic: 46.6 | Inclusion: all patients undergoing CTC from 1997-2005 Exclusion: NR, implies no exclusions | Total CT Colonoscopies: 21923 [underlined: Screening (asx):] 11707 [underlined: Diagnostic (sx):] 10216 Total incomplete procedures: NR | Total Perforations: 2/21923 (0.009%) [underlined: Screening:] 0/11707 (0% [underlined: Diagnostic:] 2/10216 (0.02%) | NR | [underlined: Exacerbated acute renal failure:] 2/21,923 (0.009%) [underlined: Chest pain (not MI):] 1/21,923 (0.0045%) | Good
Edwards 2004 ^189^ Fair | Australia General risk screening population, randomly selected from voting database Prospective Cohort | Operator: 2 MD Experience: >120 CTC exams each | Age (range): 50–54 and 65–69 % female: 49.2 % ethnic origin: NR SES % high SES: 32.5 % med SES: 33.7 % low SES: 33.7 % symptomatic: 0 | Inclusion: age 50–54; 65–69 Exclusion: personal hx of polyps or CRC, first-degree relative with CRC, CRC screening past 5 years, hx of rectal bleeding, change in bowel habit, wt loss, or severe medical illness. | Total CT Colonoscopies: 340 Total incomplete procedures: NR | Total Perforations: NR | <5mSv | Syncope- 3 from mag citrate/SPS bowel prep (abandoned, so no denominator known) No adverse events from PEG/SPS bowel prep Minor events- mild nausea, abdominal pain, flushing/sweating | Good
Sosna 2006 ^191^ Fair | Israel, 11 outpatient imaging centers All CTC during 48 month period Retrospective Cohort | Operator: Staff radiologists, resident radiologists, 6 non-academic centers: non-radiologist physicians | Age, mean: 59.9 yr % female: 42.4 % ethnic origin: NR SES: NR % symptomatic: NR | Inclusion: all patients undergoing CTC from 2001 to 2004 Exclusion: NR, implies no exclusions | Total CT Colonoscopies: 11870 Total incomplete procedures: NR | Total Perforations: 7/11870 (0.06%) [underlined: Screening:] 1/11870 (0.008%) [underlined: Diagnostic:] 6/11870 (0.05%) | NR | NR | Fair
Pickhardt 2003 ^136^ Fair | Multicenter (3), US Avg. risk screening population, recruitment through referrals for screening colonoscopy Prospective Cohort | Operator: 6 Radiologist Experience: minimum of 25 CTC read | Age, mean: 57.8 yr % female: 41.0 % ethnic origin: NR SES: NR % symptomatic: 0 | Inclusion: 50–79 yr, avgerage risk, or 40+ with a family history of CRC, 2002-2003 Exclusions: FOBT positive; iron deficiency anemia; rectal bleeding; unintentional weight loss; previous CTC or barium enema; personal history of adenomatous polyps, CRC, IBD; history of FAP or HNPC; rejection for CTC; medical condition precluding NaP prep; pregnancy | Total CT Colonoscopies: 1247 Total incomplete procedures: 6/1253 (99.5%) | Total Perforations: NR | NR | Reported no adverse effects | Good

## Table 2. Key question 3B excluded studies

Banerjee S, Van Dam J. CT colonography for colon cancer screening. Gastrointest Endosc. 2006;63:121-133. Excluded for study design. [pmid: 16377329].
Blue Cross Blue Shield Association. CT colonography (‘virtual colonoscopy’) for colon cancer screening. 2004. Chicago IL: Blue Cross Blue Shield Association (BCBS). Excluded for study design
Brenner DJ, Georgsson MA. Mass screening with CT colonography: should the radiation exposure be of concern?. Gastroenterology. 2005;129(1):328-37. Excluded for study design. [pmid: 16012958].
Brenner H, Arndt V, Stegmaier C, Ziegler H, Sturmer T. Reduction of clinically manifest colorectal cancer by endoscopic screening: empirical evaluation and comparison of screening at various ages. European Journal of Cancer Prevention. 2005;14(3):231-7. Excluded for study design. [pmid: 15901991].
Buls N, de MJ, Covens P, Stadnik T. Health screening with CT: prospective assessment of radiation dose and associated detriment. Jbr-Btr: Organe de la Societe Royale Belge de Radiologie. 2005;88:12-16. Excluded for study design.
Burling D, Halligan S, Slater A, Noakes MJ, Taylor SA. Potentially serious adverse events at CT colonography in symptomatic patients: national survey of the United Kingdom. Radiology. 2006;239(2):464-71. Excluded for study quality. [pmid: 16569789].
Cole SR, Young GP, Esterman A, Cadd B, Morcom J. A randomised trial of the impact of new faecal haemoglobin test technologies on population participation in screening for colorectal cancer. J Med Screen. 2003;10:117-122. Did not report necessary outcomes. [pmid: 14561262].
Florie J, van Gelder RE, Stoker J. Colonography by computed tomography. European Journal of Gastroenterology & Hepatology. 2005;17:809-813. Excluded for study design. [pmid: 16003128].
Frush DP, Applegate K. Computed tomography and radiation: understanding the issues. J Am Coll Radiol. 2004;1:113-119. Excluded for study design. [pmid: 17411538].
Gluecker TM, Johnson CD, Harmsen WS, et al. Colorectal cancer screening with CT colonography, colonoscopy, and double-contrast barium enema examination: prospective assessment of patient perceptions and preferences. Radiology. 2003;227(2):378-84. Did not report necessary outcomes. [pmid: 12732696].
Hur C, Gazelle GS, Hsu EH, Halpern EF, Podolsky DK. The effect of prior colonic imaging on endoscopic productivity: potential impact of computed tomographic colonography. Clinical Gastroenterology & Hepatology. 2005;3(11):1124-7. Excluded for study relevance. [pmid: 16271344].
Khan KY, Xiong T, McCafferty I, et al. Frequency and impact of extracolonic findings detected at computed tomographic colonography in a symptomatic population. British Journal of Surgery. 2007;94(3):355-61. Excluded for study relevance. [pmid: 17262750].
Limburg PJ, Fletcher JG. Making sense of CT colonography-related complication rates. Gastroenterology. 2006;131:2023-2024. Excluded for study design. [pmid: 17188968].
Macari M, Bini EJ. CT colonography: where have we been and where are we going?. Radiology. 2005;237(3):819-33. Excluded for study design. [pmid: 16237143].
Marin Gabriel JC, Rodriguez MS, de la Cruz BJ, et al. Electrolytic disturbances and colonoscopy: bowel lavage solutions, age and procedure. Revista Espanola de Enfermedades Digestivas. 2003;95(12):863-75. Did not include one of the specific screening tests. [pmid: 14972007].
Marshall KG. Population-based fecal occult blood screening for colon cancer: will the benefits outweigh the harm?. CMAJ Canadian Medical Association Journal. 2000;163:545-546. Excluded for study design. [pmid: 11006766].
Nakama H, Kamijo N, Fujimori K, Horiuchi A, Fattah AS, Zhang B. Characteristics of colorectal cancer with false negative result on immunochemical faecal occult blood test. J Med Screen. 1996;3:115-118. Did not report necessary outcomes. [pmid: 8946304].
Neri E, Caramella D, Vannozzi F, Turini F, Cerri F, Bartolozzi C. Vasovagal reactions in CT colonography. Abdom Imaging. 2007;32:552-555. Excluded population. [pmid: 17938996].
O'Hare A, Fenlon H. Virtual colonoscopy in the detection of colonic polyps and neoplasms. Best Practice & Research in Clinical Gastroenterology. 2006;79–92. Excluded for study design
Ontario Ministry of Health and Long-Term Care. Computed tomographic colonography (virtual colonoscopy). 2003. Toronto: Medical Advisory Secretariat, Ontario Ministry of Health and Long-Term Care (MAS). Excluded for study design
Prokop M. Cancer screening with CT: dose controversy. Eur Radiol. 2005;15:D55-D61. Excluded for study design. [pmid: 16479648].
Sallam BM, Pilch-Kowalczyk A, Gruszczyska K, Baron J, Pugliese F. Diagnostic performance of CT colonography in a population with high prevalence of large bowel disease. Medical Science Monitor. 2007;13(Suppl 1):105-10. Excluded for population. [pmid: 17507894].
Sosna J, Morrin MM, Kruskal JB, Lavin PT, Rosen MP, Raptopoulos V. CT colonography of colorectal polyps: a metaanalysis. AJR Am J Roentgenol. 2003;181:1593-1598. Excluded for study design. [pmid: 14627580].
Sosna J, Sella T, Bar-Ziv J, Libson E. Perforation of the colon and rectum—a newly recognized complication of CT colonography. Seminars in Ultrasound, CT & MR. 2006;27(2):161-5. Excluded for study design.
Taylor SA, Halligan S, O'Donnell C, et al. Cardiovascular effects at multi-detector row CT colonography compared with those at conventional endoscopy of the colon. Radiology. 2003;229:782-790. Excluded for population. [pmid: 14657316].
van Gelder RE, Florie J, Stoker J. Colorectal cancer screening and surveillance with CT colonography: current controversies and obstacles. Abdominal Imaging. 2005;30(1):5-12. Excluded for study design. [pmid: 15647865].
Zhang B, Fattah A, Nakama H. Characteristics and survival rate of elderly patients with colorectal cancer detected by immunochemical occult blood screening. Hepatogastroenterology. 2000;47:414-418. Excluded for study relevance. [pmid: 10791202].

## elected studies addressing extra-colonic findings on CT colonography

Table 3 Selected studies addressing extra-colonic findings on CT colonography

Study, Year (Reference) Study Design | Population, nFollow-up | Description of Extracolonic Findings (as Reported in Study) | Work-up of Extracolonic Findings (with Final Disposition at End of Study)
“Average-risk” populations
Pickhardt et al., 2008 ^341^ Prospective cohort study | 2195 Asymptomatic Follow-up: chart review, up to 18 mo | 9.3% (204 of 2195) at least “moderate” or “high” clinical significance | 7.2% (157 of 2195) recommended to have additional diagnostic evaluation 6.1% (133 of 2195) had additional diagnostic evaluation 2.5% (55 of 2195) with confirmed diagnosis of an unsuspected condition of at least “moderate” importance 1.0% (22 of 2195) required surgical procedures as follow-up
Kim et al., 2007 ^182^ Prospective cohort study | 3120 98% asymptomatic Follow-up: NR | 2.2% (70 of 3120) persons with potentially important finding (C-RADS E4) 8.5% (265 of 3120) persons with probably unimportant finding (C-RADS E3) 47.8% (1490 of 3120) persons with clinically unimportant finding (C-RADS E2) | 7.7% (241 of 3120) recommended to have additional diagnostic evaluation 0.3% (8 of 3120) persons with extracolonic malignancy (treatment NR)
Pickhardt et al., 2007 ^342^ Prospective cohort study | 2014 Presumed asymptomatic Follow-up: chart review, unclear duration | Only evaluated extracolonic GI tumors 0.5% (10 of 2014) persons with focal extracolonic GI tumors | 0.5% (10 of 2014) had further diagnostic evaluation 0.3% (7 of 2014) required surgical resection 0.05% (1 of 2014) required endoscopic resection All GI tumors found to be benign
Chin et al., 2005 ^235^ Prospective cohort study | 432 Asymptomatic Follow-up: through general practitioner, 2 y | 27.3% (118 of 432) persons with any extracolonic findings 7.4% (32 of 432) persons with clinically relevant extracolonic findings | 7.4% (32 of 432) required further diagnostic evaluation: 1.8% (8 of 432) cancer or aneurysms 5.5% (24 of 432) benign lesions 1.4% (6 of 432) ongoing follow-up at 2 y, none required treatment at 2 y
Gluecker et al., 2003 ^343^ Prospective cohort study | 681 Asymptomatic Follow-up: chart review, at least 12 mo | 69% (469 of 681) persons with any extracolonic finding 10% (71 of 681) persons with findings of “high” clinical importance 27% (183 of 681) persons with findings of “moderate” clinical importance | Total 94 follow-up diagnostic procedures 15 follow-up diagnostic procedures in 183 persons with “moderate” findings 1% (9 of 681) needed treatment
Pickhardt et al., 2003 ^136^ Prospective cohort study | 1245 Asymptomatic Follow-up: NR | 4.5% (56 of 1245) persons with findings of “high” clinical importance >13% (169 of 1245) persons with findings of “moderate” clinical importance | 0.4% (5 of 1245) extracolonic malignancy (treatment NR)
Asymptomatic surveillance populations
Ginnerup Pederson et al., 2003 ^344^ Prospective cohort study | 75 Asymptomatic, undergoing surveillance Follow-up: chart review, 6 mo | 65% (49 of 75) persons with any extracolonic finding 12% (9 of 75) persons with extracolonic findings warranting additional workup | 11% (8 of 75) had further diagnostic evaluation 3% (2 of 75) had surgery because of findings or complications of workup
Hara et al., 2000 ^345^ Prospective cohort study | 264 Asymptomatic but 162 undergoing surveillance Follow-up: chart review, 7–22 mo | 41% (109 of 264) with any extracolonic findings 11% (30 of 264) persons with extracolonic findings of “high” clinical importance 17% (46 of 264) persons with extracolonic findings of “moderate” clinical importance | 6.8% (18 of 264) had further diagnostic evaluation 1.9% (5 of 264) had surgery because of malignant or nonmalignant findings 1.5% (4 of 264) required ongoing follow-up

*C-RADS = Colonography Reporting and Data System; GI = gastrointestinal; NR = not reported.