# Appendix E. Study Details. KQ3a Harms of colonoscopy and flexible sigmoidoscopy

Colonoscopy. We found 16 fair-to-good quality studies that evaluated clinically significant adverse events from colonoscopy conducted in predominantly asymptomatic persons (see Appendix E Table 1). Study details for the four trials that included colonoscopy as followup procedures for flexible sigmoidoscopy are discussed in the following section. ^6,^ ^82,^ ^173,^ ^175^

Kim and colleagues conducted a fair-quality prospective cohort study (n=3163) examining colonoscopies performed in a predominantly average-risk, asymptomatic population through a university medical center in the US. ^182^ The population mean age was 57 years old, and approximately 56 percent women. All procedures were conducted by one of ten experienced gastroenterologists. The authors reviewed all significant adverse events, defined as those requiring hospital admission and/or medical or surgical treatment. In the published manuscript, they reported only complications of perforations. The authors reported seven (0.2 percent) perforations, four of which required surgical repair.

Ko and colleagues reported their findings in a recent abstract from a fair-quality prospective cohort study (n=18,271) in the US evaluating the incidence of serious complications from screening and surveillance colonoscopy in persons enrolled through the Clinical Outcomes Research Initiative (CORI). ^177^ Additional information was obtained through personal communication with the study investigators. ^183^ This study was given a fair-quality rating, instead of good quality rating, because full details in manuscript form are not yet available, and the investigators are currently determining if any of those persons lost to follow-up died. Approximately 90 percent of the population was age 50 to 79 years, and 45 percent were women. All procedures were conducted by 89 gastroenterologists at 19 separate practice sites; trainees participated in approximately 10 percent of the procedures. They reported all serious adverse events for persons with followup at 30 days. Their cohort included an additional 3,104 persons at the 7-day followup, who were lost to followup at 30 days. In total, they found 45 (0.25 percent) serious complications, including 4 (0.02 percent) perforations, 25 (0.14 percent) episodes of bleeding requiring hospitalization, five (0.03 percent) cases of diverticulitis requiring hospitalization, and two (0.02 percent) post-polypectomy syndrome. The authors found no deaths in the persons with 30-day followup and are currently determining if any of those persons lost to followup died.

Rathgaber and colleagues conducted a fair-quality retrospective cohort study (n procedures =12,407) looking at all colonoscopies performed between 2002 and 2004 through a large multi-specialty community group practice in the US. ^172^ The population's mean age was approximately 60 years and 52 percent women. Eight gastroenterologists conducted all procedures. Their main outcome measures were any perforation or bleeding complications within 30 days of colonoscopy. In total, they found 14 (0.11 percent) serious complications, including two (0.02 percent) perforations, 11 (0.09 percent) episodes of bleeding requiring hospitalization, and one (0.008 percent) cerebral vascular accident (CVA).

Levin and colleagues conducted a fair-quality retrospective cohort study (n procedures =16,318) looking at all colonoscopies performed in an asymptomatic population between 1994 and 2002 in a large HMO in the US. ^185^ The indications for colonoscopy were positive screening test, surveillance, or primary screening. There were a total of 11,083 polypectomies. The population's mean age was approximately 62 years and 40 percent were women. Nearly all procedures were conducted by physician endoscopists. Ninety six percent of these physician endoscopists were gastroenterologists. The study's main outcome measures were serious complications requiring hospitalization and deaths within 30 days of colonoscopy. In total, they found 44 (0.27 percent) serious complications requiring hospitalization, including 15 (0.09 percent) perforations, 15 (0.09 percent) episodes of bleeding, six (0.04 percent) cases of diverticulitis, six (0.04 percent) post-polypectomy syndrome, and two (0.01 percent) other serious complications. They also found a total of 10 deaths. Only one (0.006 percent) death, however, appeared to be directly related to colonoscopy with polypectomy.

Ko and colleagues conducted a fair-quality prospective cohort study (n=502) evaluating colonoscopies performed in an asymptomatic population at a university medical center in the US. ^176^ The population was age 40 years and older, approximately 58 percent were aged 50 to 59 years and 51 percent were women. Eight gastroenterologists conducted all procedures. The study's outcome measures included both major and minor complications, as well as patient perceptions after colonoscopy. In total, they found eight (1.6 percent) serious complications that they defined as requiring unexpected medical attention, including hospitalization or an emergency department or clinic visit.

Lee and colleagues conducted a fair-quality prospective cohort study (n=1000) looking at colonoscopies performed in an asymptomatic population at a university hospital in Taiwan. ^178^ The population was age 19 years and older with a mean age of 51 years, and 43 percent women. All procedures were conducted by seven gastroenterologists. The study's main outcome measure was assessment of post procedural abdominal pain. While the authors found three (0.3 percent) persons with severe abdominal pain, it is unclear if these cases required additional medical attention. The authors state that no complications were noted during their study followup, therefore these three cases are not included in the meta-analysis for total serious complications from colonoscopy.

Cotterill and colleagues conducted a fair-quality prospective cohort study (n=324) looking at colonoscopies performed in an asymptomatic population through a rural practice in Canada. ^174^ The population was age 22 to 80 years and 44 percent were women. Two family practice physicians conducted all procedures. The study's outcome measures included perforation, bleeding requiring hospitalization, and problems related to sedation requiring hospitalization. The study found no serious complications.

Pickhardt and colleagues reported a fair-quality prospective study that was designed to evaluate CT colonography for colorectal cancer screening in an average-risk population in three US medical centers. ^136^ Colonoscopies (n= 1239) were performed as a reference standard. The population was age 40 to 79 years, with an average age of 58 years old, and 41 percent were women. All colonoscopies were conducted by physician endoscopists, 14 were gastroenterologists and three were colorectal surgeons. While the duration of followup for adverse events is unclear, they found one (0.08 percent) episode of delayed bleeding requiring hospitalization after polypectomy. The authors did not report any other significant adverse events from colonoscopy.

Korman and colleagues conducted a fair quality large retrospective cohort study (n procedures =116,000) looking at all colonoscopies performed in 1999 through 45 endoscopic ambulatory surgery centers in the US. ^170^ General population characteristics and indications for colonoscopy are not described. All procedures were conducted by 264 gastroenterologists. The study's outcome measure was perforation. The population with complications had a mean age of 70 years and was 73 percent women. In total, they found 37 (0.03 percent) perforations. They did not consider other types of adverse events.

Nelson and colleagues conducted a good quality prospective cohort study (n=3196) evaluating colonoscopies in asymptomatic screening population between 1994 and 1997 at 13 Veteran Administration (VA) medical centers in the US. ^179^ The population was age 50 to 75 years, with a mean age of 63 years, and only three percent were women. Gastroenterologists conducted all procedures. They reported all major adverse events (i.e. requiring transfusion, hospitalization, surgery, or resulting in death) within 30 days of the colonoscopy. In total, they found 18 (0.56 percent) serious complications, including seven (0.22 percent) episodes of major bleeding, one (0.03 percent) new arrhythmia, four (0.12 percent) myocardial infarction or cerebral vascular accident, four (0.12 percent) other major complication, and one (0.03 percent) death.

Robinson and colleagues reported a fair-quality study that was part of a large randomized controlled trial designed to evaluate FOBT screening on colorectal cancer mortality in an average-risk population in the UK. ^181^ Persons who were FOBT positive received subsequent colonoscopy or double-contrast barium enema. At recruitment the study population was age 50 to 74 years. Details about endoscopists are not reported. The authors reported the adverse events for colonoscopy (n procedures = 1474) including death within 30 days of the procedure. In total, they found seven (0.47 percent) major complications, including one (0.3 percent) perforation, one (0.07 percent) major bleeding, and one (0.07 percent) snare entrapment. They found no deaths.

Newcomer and colleagues conducted a fair-quality prospective cohort study (n=250) among consecutive employed persons undergoing elective outpatient colonoscopies through a multi-specialty clinic in the US. ^180^ The population was age 18 to 70 years, with a mean age of 52 years, and 43 percent were women. Details about endoscopists are not reported. The study's main outcome measure was unplanned work absence within 7 days of colonoscopy. While they found 10 (4 percent) persons with unplanned work absence, it is unclear if these cases required additional medical attention. The authors state that no complications were noted during the study's followup period. Therefore these cases are not included in the meta-analysis for total serious complications from colonoscopy.

Flexible sigmoidoscopy. We found eight fair-to-good quality studies that evaluated clinically significant adverse events from flexible sigmoidoscopy for colorectal cancer screening in a general-risk population (see Appendix E Table 1).

Levin and colleagues conducted a fair-quality retrospective cohort study (n procedures =109,534) looking at all flexible sigmoidoscopies performed in an average-risk screening population for colorectal cancer between 1994 and 1996 in a large HMO in the US. ^185^ The population was age 50 to 79 years, mean age 61 years, and 48 percent were women. All procedures were conducted by gastroenterologists, other physicians, nurses or physician assistants. The study's main outcome measures were complications requiring hospitalization within 4 weeks of the procedure. In total, they found five cardiovascular deaths that may have been attributed to the procedure (0.004 percent) and 24 total complications (0.02 percent). There were only seven were ‘serious’ adverse events (0.006 percent), which included two perforations, two lower GI bleeds requiring transfusion, two diverticulitis, and one unexplained colitis.

Segnan and colleagues reported a fair-quality study that used the baseline results from a large ongoing multi-center randomized controlled trial in Italy to evaluate once-only flexible sigmoidoscopy screening in an average-risk screening population for colorectal cancer. ^82^ The population was age 55 to 64 years, and 50 percent were women. Gastroenterologists in hospital endoscopy units conducted all procedures. The authors reported the adverse events for the flexible sigmoidoscopies (n procedures = 9911) and followup colonoscopies (n procedures = 775). In total, they found one (0.01 percent) perforation and one (0.01 percent) severe abdominal pain from flexible sigmoidoscopy, and one (0.1 percent) perforation and one (0.1 percent) significant bleed from colonoscopy. They also found 60 (0.6 percent) minor self-limited complications from flexible sigmoidoscopy and 30 (four percent) minor self-limited complications from colonoscopy. These complications included chemical colitis, allergic reaction, mild vagal symptoms, abdominal pain, self-limited bleeding, and two seizures in persons receiving anti-epileptic treatment.

Jain and colleagues conducted a fair-quality retrospective cohort study (n procedures =5017) evaluating all flexible sigmoidoscopies performed in an average-risk screening population for colorectal cancer between 1995 and 2001 at a large HMO in the US. ^184^ The population was age 50 to 75 years, or greater than 75 years without major medical conditions. Registered gastroenterology nurses conducted all procedures. The authors reported that they found no deaths or complications from perforation, bleeding, or infection. It is unclear if they looked for all serious adverse events, therefore this study is not included in the meta-analysis for total serious complications from flexible sigmoidoscopy.

Wallace and colleagues conducted a fair-quality prospective cohort study (n procedures =3701) looking at flexible sigmoidoscopies performed in an average risk screening population for colorectal cancer between 1995 and 1997 in a large HMO in the US. ^186^ The population included individuals age 50 years and older, mean age 59 years, and 50 percent were women. Most procedures were conducted by gastroenterologists, and some by trained nonphysician staff (e.g., nurse practitioner and physician assistants). The study's outcome measures included both major and minor complications. They found no major complications, including death, perforation, or bleeding requiring transfusions.

Thiis-Evensen and colleagues reported a fair-quality study that was part of a larger population-based randomized controlled trial in Norway evaluating colorectal cancer screening in an average-risk population. ^6^ At recruitment, the population was age 50 to 59 years, average age at followup was 67 years, and the population included 50 percent women at baseline and 48 percent were women at followup. The authors reported the adverse events for the baseline and follow-up flexible sigmoidoscopies, n procedures = 446, and follow-up colonoscopies, n procedures = 521. They found no major complications, including perforation or bleeding, except for one person who was briefly hospitalized for “water intoxication,” after bowel preparation.

Kewenter and colleagues reported a fair-quality study that is part of a larger population based randomized controlled trial in Sweden to evaluate colorectal cancer screening in an average-risk population. ^175^ Persons who were FOBT positive received subsequent endoscopy (either flexible sigmoidoscopy or colonoscopy) or double-contrast barium enema. The population was age 60 to 64 years at recruitment. Details about endoscopists were not reported. The authors reported the adverse events for the flexible sigmoidoscopies (n procedures = 2108) and colonoscopies (n procedures = 190). In 113 cases, colonoscopies were performed for possible adenomas above the sigmoid colon seen on barium enema. They found three (0.14 percent) perforations from flexible sigmoidoscopy, two (1.05 percent) perforations from colonoscopy, and one (0.5 percent) major bleeding from colonoscopy. All perforations and major bleeding episodes were from polypectomies.

Atkin and colleagues reported a fair-quality study that represents the pilot results from a large ongoing multi-center randomized controlled trial in the UK to evaluate once-only flexible sigmoidoscopy screening in an average-risk screening population for colorectal cancer. ^173^ The population included individuals age 55 to 64 years. Details about endoscopists were not reported. The authors reported the adverse events for flexible sigmoidoscopies (n procedures = 1285) and follow-up colonoscopies (n procedures = 76). While they found a total of 40 bleeding episodes, it is unclear the significance of these episodes (i.e. major versus minor), and if they were from flexible sigmoidoscopy or colonoscopy. They also found three (0.2 percent) other complications from flexible sigmoidoscopy, including myocardial infarction, syncope, and severe diarrhea.

Viiala and colleagues reported a fair-quality study that represents the initial cohort of persons in a prospective cohort study of a community based flexible sigmoidoscopy CRC screening program in Western Australia. ^187^ The population included individuals age 55 to 64 years. Endoscopists were gastroenterologist, surgeons, or supervised registrars and general practitioners. The authors reported the adverse events for flexible sigmoidoscopies (n procedures = 3402). They found no perforation or significant bleeding during the screening period. It is unclear if they looked for all serious adverse events, therefore this study is not included in the meta-analysis for total serious complications from flexible sigmoidoscopy.

Table 1 Evidence table for KQ3A

Study Quality | Setting/Study Design | Screening test operator characteristics | Inclusion/ Exclusion Criteria | Patient Characteristics | Procedure Information | FollowUp | Mortality | Perforation or bleeding | Other major adverse effects | Applicability
Colonoscopy
Kim 2007 ^182^ | Prospective Cohort Single institution, US Recruitment through referrals for screening colonoscopy | Operator: 5 gastroenterologists | Inclusion: Referral from PCP for CRC screening Exclusions: Polyp surveillance, history of bowel disorder (e.g., inflammatory bowel disease, the polyposis syndrome, HNPCC) | Age: 57.0 (mean) % female: 56. % ethnic origin: NR SES: NR % symptomatic: 2 | Colonoscopies: 3163 Completion Rate: Unknown | NR | NR | Perforation Total: 7/3163 (0.2%) Polypectomy: NR 4 of the 7 required surgical intervention Bleeding Total: NR Polypectomy: NR | No other adverse effects reported | Good
Ko 2007 ^177^ Fair | Multicenter, enrolled in Clinical Outcomes Research Initiative (CORI), US Prospective Cohort | Operator: 89 gastroenterologists at 19 different practice sites Experience: Trainees participated in 10% of procedures # procedures performed: NR | Inclusion: Age 40+, undergoing colonoscopy at a participating CORI site, average risk screening, surveillance, or evaluation of another abnormal screening test Exclusion: Recent visible gastrointestinal bleeding, personal history of inflammatory bowel disease, incomplete colonoscopy due to poor bowel preparation | Age: 40–49 years: 5.7% 50–59 years: 37.5% 60–69 years: 31.2% 70–79 years: 20.2% >=80 years: 5.4% % female: 45 % ethnic origin: White: 90.3 AA: 7.6 Asian/PI: 1.4 Hispanic: 1.3 Native American: 0.5 Unknown: 0.3 % symptomatic: 0% | Colonoscopies: 18271 Completion Rate: 100% | 30 days | Total: NR Polypectomy: NR | Perforation Total: 4/18271 (0.02%) Polypectomy: NR Bleeding Total: 25/18271 (0.14%) bleeding requiring hospitalization Polypectomy: NR | Total: [underlined: All serious:] 45/18271 (0.25%) [underlined: Diverticulitis requiring hospitalization:] 5/18271 (0.03%) [underlined: Post-polypectomy syndrome:] 2/18271 (0.02%) | Good
Levin 2006 ^171^ Fair | Kaiser Permanente, Northern California Region (KPNC), US Retrospective Cohort | Operator: [underlined: Gastroenterologists]: 96% [underlined: Internists:] 2% [underlined: Not identified:] 2% Experience: NR # procedures performed: 80% <150 procedures | Inclusion: 1994 to 2002, age 40+, f/u for positive screening test, surveillance for previous polyp or CRC, primary screening Exclusion: Symptomatic | Mean Age: 62 % female: 40.3 % ethnic origin: NR % symptomatic: 0 | Colonoscopies: 16318 Completion Rate: 464/16318 (2.8%) 25% missing data on depth of completion | 30 days | Total: 10/16,318 (0.06%) Polypectomy: 1/16,318 (0.006%) | Perforation Total: 15/16318 (0.09%) Polypectomy: 12/11083 (0.11%) Bleeding Total: [underlined: Any bleeding:] 53/16318 (0.32%) [underlined: Serious bleeding:] 15/16318 (0.09%) Polypectomy: [underlined: Any bleeding:] 53/11083 (0.48%) [underlined: Serious bleeding:] 15/11083 (0.13%) | Total: [underlined: All serious:] 44/16,318 (0.2%) [underlined: Postpolypectomy syndrome:] 6/16318 (0.04%) [underlined: Diverticulitis:] 6/16,318 (0.04%) [underlined: Other serious illness:] 2/16,318 (0.01%) Polypectomy: [underlined: All serious:] 78/11083 (0.70%) [underlined: Postpolypectomy syndrome:] 6/11,083 (0.06%) [underlined: Diverticulitis:] 5/11083 (0.05%) [underlined: Other serious illness:] 2/11,083 (0.02%) | Good
Cotterill 2005 ^174^ Fair | Rural Ontario, Canada Prospective Cohort | Operator: 2 FP Experience: NR # procedures performed: NR | Inclusion: Age 50–75 average risk, or with a family history of CRC if younger than 50 Exclusion: Life expectancy <10 years, clinical indication for colonoscopy, previous colonoscopy in last 10 years, contraindications to colonoscopy | Age (range): 22–80 % female: 44.1 % ethnic origin: NR % symptomatic: NR | Colonoscopies: 324 (152 screening) Completion Rate: 94% | NR | Total: NR Polypectomy: NR | Perforation Total: 0/152 (0%) Bleeding Total: 0/152 (0%) | No other adverse effects reported | Good
Rathgaber 2006 ^172^ Fair | Western Wisconsin; Multi-specialty community group practice Retrospective Cohort | Operator: 8 Gastroenterologists Experience: NR # procedures performed: NR | Inclusion: Included all colonoscopies done from 2002-2004 Exclusion: NR | Age: 59.7 % female: 52.2 % ethnic origin: NR % symptomatic: NR | Colonoscopies: 12407 Completion Rate: 98.4% | 30 days | Total: NR Polypectomy: NR | Perforation Total: 2/12407 (0.016%) (perforations in diagnostic colonoscopies) Polypectomy: 0/5074 (0%) Bleeding Total : [underlined: Any bleeding]: 25/12407 (0.20%) [underlined: Requiring transfusions:] 11/12,407 (0.09%) Polypectomy: 23/5074 (0.46%) | Total: 28/12,407 (0.22%) [underlined: Posterior circulation cerebral vascular event:]1/12,407 (0.008%) Polypectomy: [underlined: Posterior circulation cerebral vascular event:]1/5074 (0.02%) | Fair
Newcomer 1999 ^180^ Fair | Minneapolis, MN; Large multispecialty clinic Prospective Cohort | Operator: NR Experience: NR # procedures performend: NR | Inclusion: Age 18–70 years, full-time or part-time employed, scheduled to work the following day Exclusion: Not specified | Age: 52.0 % female: 42.6% % ethnic origin: NR % symptomatic: NR | Colonoscopies: 270 (results for 250 reported) Completion Rate: 98% | 7 days | Total: 0 Polypectomy: 0 | Perforation Total: 0 Bleeding Total: 0 | Total: Unplanned work absence: 10/250 (4%) | Fair
Korman 2003 ^170^ Fair | Multiple endoscopic ambulatory surgery centers in US Retrospective Cohort | Operator: 264 Gastroenterologists Experience: NR # procedures performed: NR | Inclusion: All patients with perforation in 1999 Exclusion: Not specified | Only given those with perforation: Age: 69.4 % female: 73 % ethnic origin: NR % symptomatic: NR | Colonoscopies: 116000 Completion Rate: NR | NR | Total: NR Polypectomy: NR | Perforation Total: 37/116000 (0.03%) Polypectomy: 0 Bleeding Total: NR Polypectomy: NR | No other adverse effect reported | Fair
Nelson 2002 ^179^ Good | 13 VA Medical Centers, US Prospective Cohort | Operator: Gastro Experience (range): 1–23 # procedures performed: Avg p/y 100–750 | Inclusion: Age 50–75, from 1994-1997, asymptomatic screening Exclusion: Symptoms of lower GI disease, rectal bleeding past 6 mo, significant change in bowel habits, abdominal pain, prior colonic disease (including polyps), prior exam w/I 10 yrs, significant medical problems, limited life expectancy, need for special precaution, women of childbearing potential | Mean age: 63.0 % female: 3.2 % ethnic origin: NR % symptomatic: 0 | Colonoscopies: 3196 Completion Rate: 3107/3196 (97.2%) | 30 days | Total: 1/3196 (.03%) Polypectomy: NR | Perforation Total: 0 Bleeding Total: [underlined: Major bleeding requiring hosp, transfusion or surgery:] 7/3196 (0.22%) [underlined: Minor bleeding:] 6/3196 (0.22%) Polypectomy: 7/1672 (0.42%) | Total: [underlined: All serious:] 18/3196 (0.56%) [underlined: New arrythmia]: 1/3196 (0.03%) [underlined: MI/CVA:] 4/3196 (0.12%) [underlined: Other major:] 4/3196 (0.12%) [underlined: Vasovagal:] 188/3196 (5.4%) [underlined: Oxygen desat:] 141/3196 (4.4%) [underlined: Abdominal pain last >2 hr:] 24/3196 (0.8%) [underlined: Abdominal pain resulting in colo termination:] 29/3196 (3.9%) | Good/fair
Ko 2006 ^176^ Fair | Academic medical center, Seattle, WA, US Prospective Cohort | Operator: 8 endoscopists Experience: NR # procedures performed: 200–500 endoscopies in same year as study; trainee participated in 36% of procedures | Inclusion: Age 40+, undergoing colonoscopy for screening, surveillance of polyps, family history of CRC or polyps, evaluation of another abnormal screening test Exclusion: Recent history of GI bleeding, anemic, IBD | Age: 57.8% aged 50–59 % female: 50.8 % ethnic origin: [underlined: white :]92.0% [underlined: Afr-Amer:] 2.6% [underlined: Asian/Pac Isl:] 3.0% [underlined: Oth/mix:] 2.4% [underlined: Hispanic:] 2.2% %symptomatic: 0 | Colonoscopies: 502 470 with followup at both 7 and 30 days; 9 persons with no followup and excluded from analyses Completion Rate:99% | 7 and 30 days | Total: NR | Perforation Total: 0 Bleeding Total: [underlined: GI Bleed requiring medical attention]: 0–6 days:2/479 (0.4%) 7–30 days:2/493 (0.4%) [underlined: Requiring blood transfusion:] 0–6 days:1/479 (0.2%) 7–30 days:1/493 (0.2%) | Total: Hospitalization: [underlined: 0–6 days:] 2/479 (0.4%) [underlined: 7–30 days:] 3/493 (0.6%) ED: [underlined: 0–6 days:] 2/479 (0.4%) [underlined: 7–30 days:] 1/493 (0.2%) | Good/fair
Robinson 1999 ^181^ Fair | UK Participants identified through Family Health Service Authority lists and general practice registries, screen positive persons with endoscopic followup RCT of FOBT | Operator: NR Experience: NR # procedures performed: NR | Inclusion: Age 50 to 75; FOBT screen positive Exclusion: Identified by their doctor as having a serious illness, including CRC, within previous 5 years | Age (range): 50–75 % female: 51.9 invited to complete FOBT Ethnic origin: NR % symptomatic: NR | Colonoscopies: 1474 Completion Rate: NR | 30 days | Total: 0 | Perforation Total: 5/1474 (0.3%) Polypectomy: NR Bleeding Total: [underlined: Major GI bleeding:] 1/1474 (0.07%) Polypectomy: NR | [underlined: Snare Entrapment:] 1/1474 (0.07%) | Good
Lee 2006 ^178^ Fair | Taiwan, university hospital Prospective Cohort | Operator: 7 endoscopists Experience: NR # procedures performed: >500 | Inclusion: Age 19 to 84, consecutive persons, “asymptomatic but susceptible” Exclusion: advanced CRC, diverticulosis, non-IBS related abdominal pain | Age: 51 % female: 43.1 % ethnic origin: Chinese: 100% % symptomatic: NR | Colonoscopies: 1000 Completion Rate: 97.6% | 24 hours | Total: NR | Perforation Total: NR Bleeding Total: NR | [underlined: Severe abdominal pain:] 3/1000 (0.3%) | Fair
Pickhardt 2003 ^136^ Fair | Multicenter (3), US Prospective cohort (comparing CTC) | Operator: Gastro: 14 Colo Surgeon: 3 Experience: NR # procedures performed: NR | Inclusion: Age 50 to 79 with average risk of CRC, or 40+ with a family history of CRC, 2002-2003 Exclusion: FOBT positive; iron deficiency anemia; rectal bleeding; unintentional weight loss; previous CT colonography or barium enema; personal history of adenomatous polyps, CRC, IBD; history of FAP or HNPC; rejection for CT colonography; medical condition precluding NaP prep; pregnancy | Age: 57.8 % female: 41.0 % ethnic origin: NR % symptomatic: 0 | Colonoscopies: 1239 Completion Rate: 99.4% | NR | Total: NR | Perforation Total: NR Bleeding Total: 1/1239 (0.08%) Polypectomy: 1 with unknown denominator | No other adverse effect reported | Good
Flexible Sigmoidoscopy
Levin 2002 ^185^ Fair | Kaiser Permanente, Northern CA, US Retrospective Cohort | Operator: Gastroenterologist, non-Gastroenterologist MD or nurse; gastroenterologists supervise flex sig facilities Experience: NR # procedures performed: NR | Inclusion: age 50–79, ‘average’ risk for CRC, with screening flex sig at KP facility in Northern CA between 1994-1996 Exclusion: h/o colorectal polyps, h/o CRC, serious family history, pts with colonoscopy same day as flex sig | Age: 61.0 % female: 48.6 % ethnic origin: NR % symptomatic: 0 | Flex Sig: 109534 Completion Rate: NR | NR | Total: 10/109,534 (0.009%) [underlined: Cardiovascular deaths] 5/109,534 (0.004%) (remaining 5 appear unrelated to flex sig) Polypectomy: NR | Perforation Total: 2/109534 (0.002%) requiring surgery Polypectomy: NR Bleeding Total: [underlined: Any bleeding:] 11/109534 (0.01%) [underlined: Serious bleeding:] 2/109534 (0.002%) Polypectomy: NR | Total: [underlined: All complications] 24/109,534 (0.02%) [underlined: All ‘serious’ complications] 7/109,534 (0.06%) [underlined: Fever] 4/109,534 (0.003%) [underlined: Abdominal pain] 4/109,534 (0.003%) [underlined: GI bleed, no transfusion] 9/109,534 (0.008%) | Good
Atkin 1998 ^173^ Fair | 22 general practices in UK in two areas (Welwyn Garden City and Leicester) RCT | Operator: NR Experience: NR # procedures performed: NR | Inclusion: Age 55–64 years, asymptomatic screening population Exclusion: CRC, IBD, colorectal endoscopy within past 2 years, or severe illness | Age(Range): 55–64 % female: NR % ethnic origin: NR % symptomatic: NR | Flex Sig: 1285 Followup colonoscopies: 76 Completion Rates: NR | 1 day | Total: 0 | Perforation Total: NR Bleeding Total: 40/1285 (3.1%) Polypectomy: 14/288 (4.9%) | Total: [underlined: MI:] 1/1,285 (0.08%) [underlined: Vasovagal syncope]: 1/1,285 (0.08%) [underlined: Diarrhea:] 1/1,285 (0.08%) | Fair
Segnan 2002 ^82^ Fair | General practices, Italy RCT | Operator: Specialist gastroenterologists in hospital endoscopy units Experience: NR # procedures performed: | Inclusion: Age 55 to 64 years Exclusion: history of CRC, history of colorectal polyps, IBD, colorectal endoscopy within 2 years, family history of CRC, or medical condition that would preclude benefit from screening | Age(Range): 55–64 % female: 50.0 % ethnic origin: NR % symptomatic: NR | Flex Sig: 9911 Followup colonoscopies: 775 Completion Rate: Flex sig: 119 incomplete Colonoscopy: 188 incomplete | NR | Total: NR Polypectomy: NR | Perforation Total: [underlined: Flexible Sig]: 1/9911(0.01%) [underlined: Colonoscopy:] 1/775 (0.13%) Polypectomy: NR Bleeding Total: [underlined: Flexible Sig:] 0/9911(0%) [underlined: Colonoscopy:] 1/775 (0.13%) Polypectomy: [underlined: Colonoscopy:] 1, denominator not reported | Flex sig: [underlined: Severe abdominal pain:] 1/9911 (0.01%) [underlined: Minor self-limited complications]: 60/9911 (0.6%) Colonoscopy: [underlined: Minor self-limited complications]: 30/775 (4%) | Good/fair
Thiis-Evensen 1999 ^6^ Hoff 2001 ^188^ Fair | Population based, Norway RCT | Operator: NR Experience: NR # procedures performed: NR | Inclusion: age 50 to 59, representing an average risk population, screening Exclusion: NR | Age: i: 50–59 (range) fu: 67 (avg) % female: i: 50.0 fu: 47.9 % ethnic origin: NR SES: NR % symptomatic: i: NR fu: 17.6% IBD or abdominal complaints | Flex Sig: 446 Followup colonoscopies: 521 Completion Rate: NR | 14 days | Total: 0 Polypectomy: 0 | Perforation Total: 0 Bleeding Total: 0 | 1/415 (0.24%) water intoxication due to “over-anxious bowel cleansing” resulting in 24 hour hospital stay. | Good/fair
Wallace 1999 ^186^ Fair | HMO, US Prospective Cohort | Operator: NP: 1 PA: 2 Gastro: 15 * all trained Experience: NR # procedures performed: NR | Inclusion: Age 50 or older, no new lower GI symptoms, no acute cardiopulmonary disease, negative FOBT, no first-degree relative with CRC at 55 or younger, 1995-1997 Exclusion: NR | Age: 59 % female: 50.5 % ethnic origin: NR % symptomatic: 0 | Flex Sig: 3701 Completion Rate: NR | NR | Total: 0 | Perforation Total: 0 Bleeding Total: 0 | No other adverse effect reported | Good
Kewenter 1996 ^175^ Fair | Population based, Sweden RCT for FOBT | Operator: NR Experience: NR # of procedures performed: NR | Inclusion: Age 60–64 at the time of recruitment (recruitment was based on year of birth), FOBT positive on initial screen or positive on both initial and re-test FOBT Exclusion: NR | Age (range): 60–64 % female: NR % ethnic origin: NR % symptomatic: NR | Flex Sig: 2108 Followup colonoscopies: 190 113 colonoscopies done for proximal lesions seen on DCBE Completion Rate: NR | 1, 3, and 12 days | Total: NR | Perforation Total: [underlined: Flexible Sig:] 3/2108 (0.14%) [underlined: Colonoscopy:] 2/190 (1.05%) Polypectomy: [underlined: Flexible Sig:] 3/413 (0.7%) [underlined: Colonoscopy:] 2/113 (1.8%) Bleeding Total: [underlined: Flexible Sig:] 0/2108 (0%) [underlined: Colonoscopy:] 1/190 (0.5%) Polypectomy: [underlined: Flexible Sig:] 0/413 (0%) [underlined: Colonoscopy:] 1/113 (0.9%) | No other adverse effect reported | Fair
Jain 2002 ^184^ Fair | Kaiser Permanente, Hawaii, US Retrospective Cohort | Operator: Registered GI nurses Experience: NR # procedures performed: >50 | Inclusion: Age 50 to 75 (or above 75 if no major medical conditions), free of GI symptoms, no first degree relatives with CRC below age 60, not at high risk for CRC, negative FOBT, referral to colorectal screening clinic Exclusion: NR | Age: >50 % female: NR % ethnic origin: NR % symptomatic: 0% | Flex Sig: 5017 Completion Rate: NR | NR | Total: 0 | Perforation Total: 0/5017 (0%) Bleeding Total: 0/5017 (0%) | Reported no infections, no other adverse effects reported | Good
Viiala 2007 ^187^ Fair | Hospital conducting community based screening program, Australia Prospective Cohort | Operator: Gastroenterologists, surgeons, or supervised registrars and general practitioners Experience: NR # of procedures performed: NR | Inclusion: Age 55 to 64, asymptomatic and average-risk for CRC Exclusion: NR | Age: 60 % female: 41 % ethnic origin: NR % symptomatic: 0% | Flex Sig: 3402 Completion Rate: NR | NR | Total: NR | Perforation Total: [underlined: Flexible Sig:] 0/3402 (0%) Bleeding Total: [underlined: Flexible Sig:] 0/3402 (0%) | No other adverse effect reported | Fair

## Table 2. Key question 3A excluded studies

### Reference Reason for exclusion

Abaskharoun R, Depew W, Vanner S. Changes in renal function following administration of oral sodium phosphate or polyethylene glycol for colon cleansing before colonoscopy. Can J Gastroenterol. 2007;21:227-231. Excluded for study relevance. [pmid: 17431511].
Ainley E. Hyperphosphataemia after bowel preparation with oral sodium phosphate. Endoscopy. 2006;38(7):759. Excluded for study design. [pmid: 16810605].
Anderson JC, Pollack BJ, Shaw RD. Virtual colonoscopy. N Engl J Med. 2000;342:738-739. Excluded for study design. [pmid: 10712123].
Anderson ML, Pasha TM, Leighton JA. Endoscopic perforation of the colon: lessons from a 10-year study. American Journal of Gastroenterology. 2000;95(12):3418-22. Excluded for setting. [pmid: 11151871].
Araghizadeh FY, Timmcke AE, Opelka FG, Hicks TC, Beck DE. Colonoscopic perforations. Diseases of the Colon & Rectum. 2001;44:713-716. Excluded for setting. [pmid: 11357034].
Arora A, Singh P. Colonoscopy in patients 80 years of age and older is safe, with high success rate and diagnostic yield. Gastrointestinal Endoscopy. 2004;60(3):408-13. Excluded for population. [pmid: 15332032].
Aydogan T, Kanbay M, Uz B, et al. Fatal hyperphosphatemia secondary to a phosphosoda bowel preparation in a geriatric patient with normal renal function. Journal of Clinical Gastroenterology. 2006;40(2):177. Excluded for study design. [pmid: 16394883].
Aziz F, Milman P, McNelis J. Abdominal pain after colonoscopy: can it be acute cholecystitis?. Digestive Diseases & Sciences. 2007;52:2660-2661. Excluded for population. [pmid: 17431770].
Baillie J. Postpolypectomy bleeding. American Journal of Gastroenterology. 2007;102(6):1151-3. Excluded for study design. [pmid: 17531008].
Barkun A, Chiba N, Enns R et al. Commonly used preparations for colonoscopy: efficacy, tolerability, and safety—a Canadian Association of Gastroenterology position paper. Canadian Journal of Gastroenterology. 2006;699–710. Excluded for study design
Basson MD, Etter L, Panzini LA. Rates of colonoscopic perforation in current practice. Gastroenterology. 1998;114:1115. Excluded for study design. [pmid: 9606100].
Belsey J, Epstein O, Heresbach D. Systematic review: oral bowel preparation for colonoscopy. Alimentary Pharmacology & Therapeutics. 2007;25(4):373-84. Excluded for study relevance. [pmid: 17269992].
Beyea A, Block C, Schned A. Acute phosphate nephropathy following oral sodium phosphate solution to cleanse the bowel for colonoscopy. American Journal of Kidney Diseases. 2007;50(1):151-4. Excluded for study design. [pmid: 17591536].
Blondon H, Compan F. Feasibility of colonoscopy without sedation. A retrospective study of 502 procedures. Gastroenterologie Clinique et Biologique. 2006;30(2):328-9. Did not report necessary outcomes. [pmid: 16565675].
Boenicke L, Maier M, Merger M, et al. Retroperitoneal gas gangrene after colonoscopic polypectomy without bowel perforation in an otherwise healthy individual: report of a case. Langenbecks Arch Surg. 2006;391:157-160. Excluded for study design. [pmid: 16465554].
Bowles CJ, Leicester R, Romaya C, Swarbrick E, Williams CB, Epstein O. A prospective study of colonoscopy practice in the UK today: are we adequately prepared for national colorectal cancer screening tomorrow?. Gut. 2004;53:277-283. Excluded for population. [pmid: 14724164].
Bretthauer M, Thiis-Evensen E, Huppertz-Hauss G, et al. NORCCAP (Norwegian colorectal cancer prevention): a randomised trial to assess the safety and efficacy of carbon dioxide versus air insufflation in colonoscopy. Gut. 2002;50(5):604-7. Excluded for setting. [pmid: 11950803].
Brooker JC, Saunders BP, Shah SG, Williams CB. Endoscopic resection of large sessile colonic polyps by specialist and non-specialist endoscopists. Br J Surg. 2002;89:1020-1024. Excluded for setting. [pmid: 12153628].
Brynitz S, Kjaergard H, Struckmann J. Perforations from colonoscopy during diagnosis and treatment of polyps. Ann Chir Gynaecol. 1986;75:142-145. Excluded for setting. [pmid: 3740781].
Cammarota G, Cesaro P, Cazzato A, et al. Hydrogen peroxide-related colitis (previously known as “pseudolipomatosis”): a series of cases occurring in an epidemic pattern. Endoscopy. 2007;39:916-919. Excluded for study relevance. [pmid: 17674283].
Carl DE, Sica DA. Acute phosphate nephropathy following colonoscopy preparation. Am J Med Sci. 2007;334:151-154. Excluded study design. [pmid: 17873526].
Church J, Delaney C. Randomized, controlled trial of carbon dioxide insufflation during colonoscopy. Diseases of the Colon & Rectum. 2003;46(3):322-6. Excluded for setting. [pmid: 12626906].
Clarke GA, Jacobson BC, Hammett RJ, Carr-Locke DL. The indications, utilization and safety of gastrointestinal endoscopy in an extremely elderly patient cohort. Endoscopy. 2001;33:580-584. Excluded for population. [pmid: 11473328].
Cobb WS, Heniford BT, Sigmon LB, et al. Colonoscopic perforations: incidence, management, and outcomes. Am Surg. 2004;70:750-757. Excluded for setting. [pmid: 15481289].
Colonoscopes may spread HCV and HPV. AIDS Patient Care & Stds. 2003;17:257–258. Excluded for study design
Conigliaro R, Rossi A. Implementation of sedation guidelines in clinical practice in Italy: results of a prospective longitudinal multicenter study. Endoscopy. 2006;38:1137-1143. Excluded for setting. [pmid: 17111337].
Dafnis G, Ekbom A, Pahlman L, Blomqvist P. Complications of diagnostic and therapeutic colonoscopy within a defined population in Sweden. Gastrointestinal Endoscopy. 2001;54(3):302-9. Excluded for population. [pmid: 11522969].
de GP, Slagt C, de Graaf JL, Loffeld RJ. Fatal aspiration of polyethylene glycol solution. Netherlands Journal of Medicine. 2006;64(6):196-8. Excluded for setting. [pmid: 16788218].
de Zwart IM, Griffioen G, Shaw MP, Lamers CB, de Roos A. Barium enema and endoscopy for the detection of colorectal neoplasia: sensitivity, specificity, complications and its determinants. Clin Radiol. 2001;56:401-409. Excluded for study quality. [pmid: 11384140].
Di LF, Vigano P, Pilati S, Mantovani N, Togliani T, Pulica C. Splenic rupture after colonoscopy. A case report and review of the literature. Chir Ital. 2007;59:755-757. Excluded for study design. [pmid: 18019651].
DiPrima RE, Barkin JS, Blinder M, Goldberg RI, Phillips RS. Age as a risk factor in colonoscopy: fact versus fiction. Am J Gastroenterol. 1988;83:123-125. Excluded for setting. [pmid: 3341334].
Dobrowolski S, Dobosz M, Babicki A, Glowacki J, Nalecz A. Blood supply of colorectal polyps correlates with risk of bleeding after colonoscopic polypectomy. Gastrointest Endosc. 2006;63:1004-1009. Excluded for setting. [pmid: 16733117].
Dominitz JA, Eisen GM, Baron TH, et al. Complications of colonoscopy. Gastrointest Endosc. 2003;57:441-445. Excluded for study design. [pmid: 12665750].
Doniec JM, Lohnert MS, Schniewind B, Bokelmann F, Kremer B, Grimm H. Endoscopic removal of large colorectal polyps: prevention of unnecessary surgery?. Diseases of the Colon & Rectum. 2003;46(3):340-8. Excluded for setting. [pmid: 12626909].
Eckardt VF, Kanzler G, Schmitt T, Eckardt AJ, Bernhard G. Complications and adverse effects of colonoscopy with selective sedation. Gastrointest Endosc. 1999;49:560-565. Excluded for population. [pmid: 10228252].
Edwards JK, Norris TE. Colonoscopy in rural communities: can family physicians perform the procedure with safe and efficacious results?. Journal of the American Board of Family Practice. 2004;17(5):353-8. Excluded for population. [pmid: 15355949].
Farley DR, Bannon MP, Zietlow SP, Pemberton JH, Ilstrup DM, Larson DR. Management of colonoscopic perforations. Mayo Clin Proc. 1997;72:729-733. Excluded for setting. [pmid: 9276600].
Gatto NM, Frucht H, Sundararajan V, Jacobson JS, Grann VR, Neugut AI. Risk of perforation after colonoscopy and sigmoidoscopy: a population-based study. Journal of the National Cancer Institute. 2003;95(3):230-6. Excluded for population. [pmid: 12569145].
Gedebou TM, Wong RA, Rappaport WD, Jaffe P, Kahsai D, Hunter GC. Clinical presentation and management of iatrogenic colon perforations. Am J Surg. 1996;172:454-457. Excluded for population. [pmid: 8942543].
Gibbs DH, Opelka FG, Beck DE, Hicks TC, Timmcke AE, Gathright JB Jr. Postpolypectomy colonic hemorrhage. Dis Colon Rectum. 1996;39:806-810. Excluded for setting. [pmid: 8674375].
Gidwani AL, Makar R, Garrett D, Gilliland R. A prospective randomized single-blind comparison of three methods of bowel preparation for outpatient flexible sigmoidoscopy. Surgical Endoscopy. 2007;21(6):945-9. Excluded for study relevence. [pmid: 17149552].
Giusti de MM, Sgreccia A, Carmenini E, Morelli S. Infective endocarditis from Enterococcus faecalis complicating colonoscopy in Heyde's syndrome. Postgraduate Medical Journal. 2004;80(948):619-20. Excluded for population. [pmid: 15467002].
Gladman MA, Shami SK. Medical mystery: an unusual complication of colonoscopy—the answer.[comment]. N Engl J Med. 2007;357:2309-2310. Excluded for study design. [pmid: 18046038].
Gonlusen G, Akgun H, Ertan A, Olivero J, Truong LD. Renal failure and nephrocalcinosis associated with oral sodium phosphate bowel cleansing: clinical patterns and renal biopsy findings. Archives of Pathology & Laboratory Medicine. 2006;130(1):101-6. Excluded for study design. [pmid: 16390223].
Gupta A. Splenic rupture following colonoscopy: rare in the U.K.?. Surgeon Journal of the Royal Colleges of Surgeons of Edinburgh & Ireland. 2006;4(6):389. Excluded for study relevance. [pmid: 17152206].
Hanson JM, Plusa SM, Bennett MK, Browell DA, Cunliffe WJ. Glutaraldehyde as a possible cause of diarrhoea after sigmoidoscopy. British Journal of Surgery. 1998;85(10):1385-7. Excluded for study relevance. [pmid: 9782020].
Harnik IG. Pyogenic liver abscess presenting after malignant polypectomy. Digestive Diseases & Sciences. 2007;52:3524-3525. Excluded for study design. [pmid: 17406839].
Heldwein W, Dollhopf M, Rosch T, et al. The Munich Polypectomy Study (MUPS): Prospective Analysis of Complications and Risk Factors in 4000 Colonic Snare Polypectomies. Endoscopy. 2005;37:1116-1122. Excluded for setting. [pmid: 16281142].
Ho, C., Jacobs, P., Sandha, G., Noorani, H. Z., and Skidmore, B. Non-physicians performing screening flexible sigmoidoscopy: clinical efficacy and cost-effectiveness. 2006. Ottawa: Canadian Coordinating Office for Health Technology Assessment (CCOHTA). Excluded for study relevance
Hookey LC, Depew WT, Vanner S. The safety profile of oral sodium phosphate for colonic cleansing before colonoscopy in adults. Gastrointest Endosc. 2002;56:895-902. Did not report necessary outcomes. [pmid: 12447305].
Hookey LC, Depew WT, Vanner SJ. Combined low volume polyethylene glycol solution plus stimulant laxatives versus standard volume polyethylene glycol solution: a prospective, randomized study of colon cleansing before colonoscopy. Canadian Journal of Gastroenterology. 2006;2006:101-5. Excluded for setting. [pmid: 16482236].
Hookey LC, Vanner S. A review of current issues underlying colon cleansing before colonoscopy. Canadian Journal of Gastroenterology. 2007;21(2):105-11. Excluded for study relevence. [pmid: 17299615].
Iqbal CW, Chun YS, Farley DR. Colonoscopic perforations: a retrospective review. J Gastrointest Surg. 2005;9:1229-1235. Excluded for population. [pmid: 16332478].
Johanson JF, Popp JW Jr, Cohen LB, et al. A randomized, multicenter study comparing the safety and efficacy of sodium phosphate tablets with 2L polyethylene glycol solution plus bisacodyl tablets for colon cleansing. Am J Gastroenterol. 2007;102:2238-2246. Excluded for study design. [pmid: 17573796].
Johnson C, Mader M, Edwards DM, Vesy T. Splenic rupture following colonoscopy: two cases with CT findings. Emergency Radiology. 2006;13(1):47-9. Excluded for study design. [pmid: 16915394].
Josemanders DF, Spillenaar Bilgen EJ, van Sorge AA, Wahab PJ, de Vries RA. Colonic explosion during endoscopic polypectomy: avoidable complication or bad luck?. Endoscopy. 2006;38:943-944. Excluded for setting. [pmid: 17019761].
Karajeh MA, Sanders DS, Hurlstone DP. Colonoscopy in elderly people is a safe procedure with a high diagnostic yield: a prospective comparative study of 2000 patients. Endoscopy. 2006;38(3):226-30. Excluded for setting. [pmid: 16528647].
Kastenberg D, Barish C, Burack H, et al. Tolerability and patient acceptance of sodium phosphate tablets compared with 4-L PEG solution in colon cleansing: combined results of 2 identically designed, randomized, controlled, parallel group, multicenter phase 3 trials. Journal of Clinical Gastroenterology. 2007;41(1):54-61. Excluded for study relevance. [pmid: 17198066].
Katsinelos P, Kountouras J, Paroutoglou G, et al. Endoloop-assisted polypectomy for large pedunculated colorectal polyps. Surgical Endoscopy. 2006;2006:1257-61. Excluded for setting. [pmid: 16858525].
Kavic SM, Basson MD. Complications of endoscopy. Am J Surg. 2001;181:319-332. Excluded for study quality. [pmid: 11438266].
Ker TS, Wasserberg N, Beart RW Jr. Colonoscopic perforation and bleeding of the colon can be treated safely without surgery. Am Surg. 2004;70:922-924. Excluded for setting. [pmid: 15529852].
Kim HS, Kim TI, Kim WH, et al. Risk factors for immediate postpolypectomy bleeding of the colon: a multicenter study. American Journal of Gastroenterology. 2006;101(6):1333-41. Excluded for setting. [pmid: 16771958].
Kirby E. Colonoscopy procedures at a small rural hospital. Canadian Journal of Rural Medicine. 2004;9(2):89-93. Excluded for population. [pmid: 15603681].
Ko CW, Sonnenberg A. Comparing risks and benefits of colorectal cancer screening in elderly patients. Gastroenterology. 2005;129:1163-1170. Excluded for study design. [pmid: 16230070].
Ladas SD, Karamanolis G, Ben-Soussan E. Colonic gas explosion during therapeutic colonoscopy with electrocautery. World Journal of Gastroenterology. 2007;13:5295-5298. Excluded for study design. [pmid: 17879396].
Lagares-Garcia JA, Kurek S, Collier B, et al. Colonoscopy in octogenarians and older patients. Surgical Endoscopy. 2001;15(3):262-5. Excluded for population. [pmid: 11344425].
Lambert A, Nguyen SQ, Byrn JC, Fishman EW, Shen HY. Small-bowel perforation after colonoscopy. Gastrointestinal Endoscopy. 2007;65(2):352-3. Excluded for study design. [pmid: 17137862].
Larsen IK, Grotmol T, Almendingen K, Hoff G. Impact of colorectal cancer screening on future lifestyle choices: a three-year randomized controlled trial. Clinical & Gastroenterology Hepatology. 2007;5(4):477-83. Did not report necessary outcomes.
Lee JG, Vigil H, Leung JW. A randomized controlled trial of total colonic decompression after colonoscopy to improve patient comfort. Am J Gastroenterol. 2001;96:95-100. Excluded for setting. [pmid: 11197295].
Leslie K, Tay T, Neo E. Intravenous fluid to prevent hypotension in patients undergoing elective colonoscopy. Anaesthesia & Intensive Care. 2006;34(3):316-21. Excluded for setting. [pmid: 16802483].
Levin B, Smith RA, Feldman GE, et al. Promoting early detection tests for colorectal carcinoma and adenomatous polyps: a framework for action: the strategic plan of the National Colorectal Cancer Roundtable. Cancer. 2002;95:1618-1628. Excluded for study relevance. [pmid: 12365008].
Lo AY, Beaton HL. Selective management of colonoscopic perforations. J Am Coll Surg. 1994;179:333-337. Excluded for setting. [pmid: 8069431].
Luchtefeld MA, Kim DG. Colonoscopy in the office setting is safe, and financially sound ... for now. Diseases of the Colon & Rectum. 2006;49(3):377-81. discussion 381 –2. Excluded for study quality. [pmid: 16475034].
Luebke T, Baldus SE, Holscher AH, Monig SP. Splenic rupture: an unusual complication of colonoscopy: case report and review of the literature. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2006;16(5):351-4. Excluded for study design.
Luning TH, Keemers-Gels ME, Barendregt WB, Tan AC, Rosman C. Colonoscopic perforations: a review of 30,366 patients. Surg Endosc. 2007;21(6):994-7. Excluded for setting. [pmid: 17453289].
Macrae FA, Tan KG, Williams CB. Towards safer colonoscopy: a report on the complications of 5000 diagnostic or therapeutic colonoscopies. Gut. 1983;24:376-383. Excluded for setting. [pmid: 6601604].
Marin Gabriel JC, Rodriguez MS, de la Cruz BJ, et al. Electrolytic disturbances and colonoscopy: bowel lavage solutions, age and procedure. Revista Espanola de Enfermedades Digestivas. 2003;95(12):863-75. Excluded for setting. [pmid: 14972007].
Marriott D, Stark D, Harkness J. Veillonella parvula discitis and secondary bacteremia: a rare infection complicating endoscopy and colonoscopy?. [Review] [4 refs]. Journal of Clinical Microbiology. 2007;45(2):672-4. Excluded for study design. [pmid: 17108070].
Marwan K, Farmer KC, Varley C, Chapple KS. Pneumothorax, pneumomediastinum, pneumoperitoneum, pneumoretroperitoneum and subcutaneous emphysema following diagnostic colonoscopy. Annals of the Royal College of Surgeons of England. 2007;89(5):W20-1. Excluded for study design. [pmid: 17688713].
Mathus-Vliegen EM, Kemble UM. A prospective randomized blinded comparison of sodium phosphate and polyethylene glycol-electrolyte solution for safe bowel cleansing. Alimentary Pharmacology & Therapeutics. 2006;23:543-552. Excluded for population. [pmid: 16441475].
Maule WF. Screening for colorectal cancer by nurse endoscopists. N Engl J Med. 1994;330:183-187. Excluded for setting. [pmid: 8264742].
McCallion K, Mitchell RM, Wilson RH, et al. Flexible sigmoidoscopy and the changing distribution of colorectal cancer: implications for screening. Gut. 2001;48(4):522-5. Excluded for study design. [pmid: 11247897].
Miles A, Wardle J, Atkin W. Receiving a screen-detected diagnosis of cancer: the experience of participants in the UK flexible sigmoidoscopy trial. Psychooncology. 2003;12:784-802. Excluded for study relevance. [pmid: 14681952].
Miles A, Wardle J. Adverse psychological outcomes in colorectal cancer screening: does health anxiety play a role?. Behav Res Ther. 2006;44:1117-1127. Excluded for setting. [pmid: 16243291].
Misra T, Lalor E, Fedorak RN. Endoscopic perforation rates at a Canadian university teaching hospital. Canadian Journal of Gastroenterology. 2004;18(4):221-6. Excluded for setting. [pmid: 15054498].
Mitchell RM, McCallion K, Gardiner K, Collins J, Watson P. Colonoscopy has a high diagnostic yield and low complication rate in older patients. Age & Ageing. 2002;31(4):323-5. Excluded for population. [pmid: 12147577].
Nagler J, Poppers D, Turetz M. Severe hyponatremia and seizure following a polyethylene glycol-based bowel preparation for colonoscopy. Journal of Clinical Gastroenterology. 2006;40(6):558-9. Excluded for study design. [pmid: 16825941].
Nelson D. Colonoscopy and polypectomy. Hematology - Oncology Clinics of North America. 2002;16(4):867-74. Excluded for study design.
Nelson RL, Abcarian H, Prasad ML. Iatrogenic perforation of the colon and rectum. Dis Colon Rectum. 1982;25:305-308. Excluded for setting. [pmid: 7083975].
Nivatvongs S. Complications in colonoscopic polypectomy: lessons to learn from an experience with 1576 polyps. Am Surg. 1988;54:61-63. Excluded for setting. [pmid: 3341645].
Palitz AM, Selby JV, Grossman S, et al. The Colon Cancer Prevention Program (CoCaP): rationale, implementation, and preliminary results. HMO Pract. 1997;11:5-12. Did not report necessary outcomes. [pmid: 10165556].
Parker MA, Robinson MH, Scholefield JH, Hardcastle JD. Noninvasive colorectal cancer screening. Journal of Medical Screening. 2002;9(1):7-10. Excluded for study relevance. [pmid: 11943790].
Parra-Blanco A, Kaminaga N, Kojima T, Endo Y, Tajiri A, Fujita R. Colonoscopic polypectomy with cutting current: is it safe?. Gastrointest Endosc. 2000;51:676-681. Excluded for setting. [pmid: 10840299].
Pearl JP, McNally MP, Elster EA, DeNobile JW. Benign pneumoperitoneum after colonoscopy: a prospective pilot study. Mil Med. 2006;171:648-649. Excluded for study relevance. [pmid: 16895133].
Perez RF, Gonzalez CP, Legaz Huidobro ML, et al. Endoscopic resection of large colorectal polyps. Revista Espanola de Enfermedades Digestivas. 2004;96(1):36-47. Excluded for setting. [pmid: 14971996].
Pfefferkorn U, Hamel CT, Viehl CT, Marti WR, Oertli D. Haemorrhagic shock caused by splenic rupture following routine colonoscopy. International Journal of Colorectal Disease. 2007;22(5):559-60. Excluded for study design. [pmid: 15830203].
Qadeer MA, Vargo JJ, Khandwala F, Lopez R, Zuccaro G. Propofol versus traditional sedative agents for gastrointestinal endoscopy: a meta-analysis. Clin Gastroenterol Hepatol. 2005;3:1049-1056. Excluded for study relevance. [pmid: 16271333].
Rainis T, Keren D, Goldstein O, Stermer E, Lavy A. Diagnostic yield and safety of colonoscopy in Israeli patients in an open access referral system. Journal of Clinical Gastroenterology. 2007;41(4):394-9. Excluded for population. [pmid: 17413609].
Rasmussen M, Kronborg O. Upper gastrointestinal cancer in a population based screening program with fecal occult blood test for colorectal cancer summary for patients in. Scand J Gastroenterol. 2002;37:25. Did not report necessary outcomes.
Regula J, Rupinski M, Kraszewska E, et al. Colonoscopy in colorectal-cancer screening for detection of advanced neoplasia. New England Journal of Medicine. 2006;355(18):1863-72. Excluded for study quality. [pmid: 17079760].
Rerknimitr R. Sorbitol can be the cause of colonic explosion.[comment]. Endoscopy. 2007;39(3):257. Excluded for study design. [pmid: 17385112].
Rex DK, Schwartz H, Goldstein M, et al. Safety and colon-cleansing efficacy of a new residue-free formulation of sodium phosphate tablets. American Journal of Gastroenterology. 2006;101(11):2594-604. Excluded for setting. [pmid: 17029618].
Ristikankare M, Hartikainen J, Heikkinen M, Janatuinen E, Julkunen R. The effects of gender and age on the colonoscopic examination. Journal of Clinical Gastroenterology. 2001;32(1):69-75. Excluded for population. [pmid: 11154176].
Ristikankare M, Julkunen R, Mattila M, et al. Conscious sedation and cardiorespiratory safety during colonoscopy. Gastrointest Endosc. 2000;52:48-54. Excluded for setting. [pmid: 10882962].
Rollino C, Tomasini C, Di PR, et al. Cholesterol embolism after colonoscopy: a case report. Gastrointest Endosc. 2006;63:730-732. Excluded for population. [pmid: 16564892].
Rosen L, Bub DS, Reed JF III, Nastasee SA. Hemorrhage following colonoscopic polypectomy. Dis Colon Rectum. 1993;36:1126-1131. Excluded for setting. [pmid: 8253009].
Sanaka MR, Super DM, Mullen KD, Ferguson DR, McCullough AJ. Use of tegaserod along with polyethylene glycol electrolyte solution for colonoscopy bowel preparation: a prospective, randomized, double-blind, placebo-controlled study. Alimentary Pharmacology & Therapeutics. 2006;23(5):669-74. Excluded for setting. [pmid: 16480406].
Schoenfeld PS, Cash B, Kita J, Piorkowski M, Cruess D, Ransohoff D. Effectiveness and patient satisfaction with screening flexible sigmoidoscopy performed by registered nurses. Gastrointest Endosc. 1999;49:158-162. Excluded for setting. [pmid: 9925692].
Shah P. Splenic rupture as complication of colonoscopy. Indian J Gastroenterol. 2007;26:150. Jun. Excluded for study design. [pmid: 17704599].
Shah PR, Raman S, Haray PN. Splenic rupture following colonoscopy: rare in the UK?. Surgeon Journal of the Royal Colleges of Surgeons of Edinburgh & Ireland. 2005;3(4):293-5. Excluded for study design. [pmid: 16121778].
Shah SG, Brooker JC, Thapar C, Williams CB, Saunders BP. Patient pain during colonoscopy: an analysis using real-time magnetic endoscope imaging. Endoscopy. 2002;34(6):435-40. Excluded for setting. [pmid: 12048623].
Shah SG, Brooker JC, Williams CB, Thapar C, Saunders BP. Effect of magnetic endoscope imaging on colonoscopy performance: a randomised controlled trial. Lancet. 2000;356:1718-1722. Excluded for setting. [pmid: 11095259].
Shah SG, Saunders BP, Brooker JC, Williams CB. Magnetic imaging of colonoscopy: an audit of looping, accuracy and ancillary maneuvers. Gastrointest Endosc. 2000;52:1-8. Excluded for setting. [pmid: 10882954].
Shapero TF, Alexander PE, Hoover J, Burgis E, Schabas R. Colorectal cancer screening: video-reviewed flexible sigmoidoscopy by nurse endoscopists—a Canadian community-based perspective. Can J Gastroenterol. 2001;15:441-445. Excluded for setting. [pmid: 11493949].
Sica DA, Carl D, Zfass AM. Acute phosphate nephropathy—an emerging issue. Am J Gastroenterol. 2007;102:1844-1847. Excluded for study design. [pmid: 17727428].
Smith RR, Ragput A. Mucosal tears on endoscopic insufflation resulting in perforation: an interesting presentation of collagenous colitis. J Am Coll Surg. 2007;205:725. Excluded for population. [pmid: 17964451].
Srivastava V, Pink J, Swarnkar K, Feroz A, Stephenson BM. Colonoscopically induced appendicitis. Colorectal Dis. 2004;6:124-125. Excluded for study design. [pmid: 15008912].
Sumanac K, Zealley I, Fox BM, et al. Minimizing postcolonoscopy abdominal pain by using CO(2) insufflation: a prospective, randomized, double blind, controlled trial evaluating a new commercially available CO(2) delivery system.[see comment]. Gastrointestinal Endoscopy. 2002;56(2):190-4. Did not report necessary outcomes. [pmid: 12145595].
Takahashi Y, Tanaka H, Kinjo M, Sakumoto K. Prospective evaluation of factors predicting difficulty and pain during sedation-free colonoscopy. Diseases of the Colon & Rectum. 2005;48(6):1295-300. Excluded for setting. [pmid: 15793639].
Tan JJ, Tjandra JJ. Which is the optimal bowel preparation for colonoscopy - a meta-analysis. Colorectal Disease. 2006;8(4):247-58. Excluded for study relevance. [pmid: 16630226].
Taupin D, Chambers SL, Corbett M, Shadbolt B. Colonoscopic screening for colorectal cancer improves quality of life measures: a population-based screening study. Health & Quality of Life Outcomes. 2006;4:82. Excluded for setting. [pmid: 17044941].
Taylor SA, Halligan S, O'Donnell C, et al. Cardiovascular effects at multi-detector row CT colonography compared with those at conventional endoscopy of the colon. Radiology. 2003;229:782-790. Excluded for population. [pmid: 14657316].
Thomas-Gibson S, Thapar C, Shah SG, Saunders BP. Colonoscopy at a combined district general hospital and specialist endoscopy unit: lessons from 505 consecutive examinations. J R Soc Med. 2002;95:194-197. Excluded for population. [pmid: 11934910].
Tiwari A, Melegros L. Colonoscopic perforation. Br J Hosp Med. 2007;68:429. Excluded for study design.
Tormey WP. Hyponatraemia after colonoscopy. Lancet. 2001;357:1621-1622. Excluded for study design. [pmid: 11386319].
Tran DQ, Rosen L, Kim R, Riether RD, Stasik JJ, Khubchandani IT. Actual colonoscopy: what are the risks of perforation?. Am Surg. 2001;67:845-847. Excluded for setting. [pmid: 11565761].
Tsoraides SS, Gupta SK, Estes NC. Splenic rupture after colonoscopy: case report and literature review. J Trauma. 2007;62:255-257. Excluded for study design. [pmid: 17215767].
Tulchinsky H, Madhala-Givon O, Wasserberg N, Lelcuk S, Niv Y. Incidence and management of colonoscopic perforations: 8 years' experience. World Journal of Gastroenterology. 2006;12(26):4211-3. Excluded for setting. [pmid: 16830377].
Viiala CH, Zimmerman M, Cullen DJ, Hoffman NE. Complication rates of colonoscopy in an Australian teaching hospital environment. Internal Medicine Journal. 2003;33(8):355-9. Excluded for population. [pmid: 12895166].
Vokurka J. Iatrogenic perforation during an endoscopic examination of the gastrointestinal tract. Bratislavske Lekarske Listy. 2004;105(1011):387-9. Did not report necessary outcomes. [pmid: 15658582].
Walter LC, Lewis CL, Barton MB. Screening for colorectal, breast, and cervical cancer in the elderly: a review of the evidence. American Journal of Medicine. 2005;118(10):1078-86. Excluded for study design. [pmid: 16194635].
Wan J, Zhang ZQ, Zhu C, et al. Colonoscopic screening and follow-up for colorectal cancer in the elderly. World Journal of Gastroenterology. 2002;8:267-269. Excluded for study quality. [pmid: 11925605].
Watanabe K, Oshitani N, Kamata N, et al. Efficacy and endoscopic prediction of cytapheresis therapy in patients with refractory and steroid-dependent ulcerative colitis. Aliment Pharmacol Ther. 2006;24(Suppl 4):147-152. Excluded for population. [pmid: 16803613].
Waye JD, Lewis BS, Yessayan S. Colonoscopy: a prospective report of complications. J Clin Gastroenterol. 1992;15:347-351. Excluded for setting. [pmid: 1294644].
Webb WA, McDaniel L, Jones L. Experience with 1000 colonoscopic polypectomies. Ann Surg. 1985;201:626-632. Excluded for population. [pmid: 3873221].
Winkleman BJ, Matthews DE, Wiebke EA. Colorectal cancer screening at a Veterans Affairs hospital. Am J Surg. 2003;186:468-471. Excluded for setting. [pmid: 14599608].
Yano H, Okada K, Monden T. Adhesion ileus caused by tattoo Excluded for study relevence
Yoong KK, Heymann T. Colonoscopy in the very old: why bother?. Postgraduate Medical Journal. 2005;81(953):196-7. Excluded for population. [pmid: 15749799].
Zerey M, Paton BL, Khan PD, et al. Colonoscopy in the very elderly: a review of 157 cases. Surg Endosc. 2007;21:1806. Excluded for study design. [pmid: 17353977].
Zubarik R, Fleischer DE, Mastropietro C, et al. Prospective analysis of complications 30 days after outpatient colonoscopy. Gastrointest Endosc. 1999;50:322-328. Excluded for setting. [pmid: 10462650].
Zubarik R, Ganguly E, Benway D, Ferrentino N, Moses P, Vecchio J. Procedure-related abdominal discomfort in patients undergoing colorectal cancer screening: a comparison of colonoscopy and flexible sigmoidoscopy. American Journal of Gastroenterology. 2002;97(12):3056-61. Excluded for setting. [pmid: 12492190].