# Appendix D. Study Details KQ2B. CT Colonography, Fecal Occult Blood Tests, and Fecal DNA

## CT Colonography

Three smaller studies only briefly mentioned in the text of the report are described here. A fair-to-poor quality study of 68 average-risk male veterans used some newer aspects of CT technology that are more sensitive (multidetector scanning) when combined with less sensitive aspects (2D imaging with 3D confirmation only as needed). ^149^ They found polyps (any histological type) in 57 percent of 68 male veterans. Per-polyp sensitivity for all polyps tended to be lower in smaller polyps (6–9 mm), compared with larger ones (10 mm or greater), although estimates were unstable due to small numbers and per patient sensitivity was not reported. Per-patient specificity was 89.7 percent (CI: 72.7, 97.8) for polyps of all sizes, and better for polyps 10 mm or greater (98.5 percent: CI 91.7, 99.9). CTC lesions not found on OC were assumed to be false positives due to fecal material.

Two small studies provide additional limited evidence on the test-performance characteristics of CTC. One study of fair-to-poor quality study examined 46 Veterans at an Indianapolis VA Hospital system and compared results from spiral CT to those from same-day colonoscopy. ^150^ Subjects were intentionally selected from a population of older men (98 percent male, mean age of 67.7 years) to increase polyp prevalence. Images were examined from 2D axial CT as well as interactive multiplanar images and 3D CTC (consisting of surface and volume-rendered images). CTC examinations employed older, single-detector technology without contrast. Three-dimensional imaging proved superior to 2D for polyp detection, although the difference was statistically significant only for lesions ranging from 6 to 9 mm. The sensitivity of three-dimensional exam met or, more commonly, exceeded that of 2D for all sizes of lesion. The per-patient sensitivity for adenomas of at least 1 cm was calculated at 89 percent. Flat adenomas in the proximal colon were notably missed by CTC. Oversight of large, flat adenomas was attributed to residual stool and water in the region or to bowel segment collapse, strengthening the case for special attention to adequate bowel preparation being central to the identification of nonpolypoid lesions.

A second study of fair-quality enrolled 42 patients in New York City enrolled subjects more representative of the general screening population, including asymptomatic middle-aged adults (mean age 56 years) of either gender (42 percent female, 58 percent male), 29 percent of whom reported a family history of CRC. ^148^ Two methods of examination included: initial review of axial 2D images with 3D reexamination only of focal areas suspicious for abnormality (Method 1). Initial review of 2D images followed by complete examination with simultaneous 3D fly-through CTC (surface-rendered images) and multiplanar reformatted images regardless of initial findings (Method 2). Examinations employed older single detector technology without contrast. Within this population, the prevalence of polyps was 31 percent (13/42) by traditional colonoscopy. Missed polyps on CTC (10 of 16) included two at 2 mm, five at 3 mm, one at 4 mm, and two at 6 mm. Sixty-seven percent of polyps measuring at least 6 mm were captured by CTC, as were 100 percent of polyps measuring at least 7 mm. Both CTC methods had similar per-polyp sensitivity (38 percent) and NPV (Method 1: 73 percent; Method 2: 72 percent), while the more targeted Method 1 outperformed Method 2 in per-polyp specificity and PPV (100 percent versus 96 percent and 100 percent versus 86 percent, respectively). Axial 2D CTC was found to be comparable to 3D CTC for detection of polyps, and the more complete and time-intensive Method 2 offered no justifiable advantage over the focal review conducted in Method 1.

## Fecal Occult Blood Tests

High-sensitivity guaiac tests. Two studies conducted in the same managed care organization evaluated the performance of Hemoccult Sensa in average-risk patients. ^159,^ ^160^ The first fair-quality study provided comparative single-test performance information for Hemoccult Sensa compared with nonrehydrated Hemoccult II ^160^ in 8104 multi-ethnic (46.5 percent nonwhite) adults aged 50 or older. Participants underwent simultaneous testing with Hemoccult Sensa, nonrehydrated Hemoccult II, and HemeSelect, followed by FS and/or colonoscopy for any positive FOBT result. All participants were followed for two years through complete medical record review, supplemented by tumor registry and pathology laboratory result reviews. This is an adequate surrogate reference standard for CRC only (not polyps). Test completion rates were similar for both tests (91.4 to 93.5 percent). The percentage of positive tests was much higher for Hemoccult Sensa (13.6 percent) compared with Hemoccult II (2.5 percent). Sensitivity of Hemoccult Sensa for CRC was significantly better than nonrehydrated Hemoccult II (79.4 vs. 37.1 percent), although PPV was poorer (Hemoccult Sensa 2.5 percent compared with 6.6 percent for Hemoccult II). Specificity of Hemoccult Sensa for CRC was likewise significantly inferior to Hemoccult II (86.7 percent vs. 97.7 percent). While this is a well-performed study, these results are limited by the design constraints of being performed in the “real-world.” As such, while comparative test performance results are available, these were not comparably determined. Only 36 percent of those with positive Hemoccult Sensa tests had colonoscopy (the remainder receiving FS with followup Hemoccult II testing over the next year as an alternative “gold standard,” a change in study protocol implemented mid-way due to very high test positivity of Hemoccult Sensa). Those with positive results on the other FOBT tests had a colonoscopy rate of 78 percent–85 percent. Thus, the sensitivity is likely to be over-estimated for Hemoccult Sensa compared with Hemoccult II and with HemeSelect, and the specificity is likely to be underestimated. What is clear is that the percentage with positive test results is about twice as high (13.6 percent), compared with 2.5 percent for Hemoccult II.

The second and more recent study was a good-quality study in which all patients (n=5841: 26 percent nonwhite; 53 percent female; 11 percent aged 70 years and older) received followup endoscopy. ^159^ Patients screening positive were advised to undergo colonoscopy and those screening negative underwent a flexible sigmoidoscopy exam. All patients were followed through medical records review for an additional 2 yrs. The study compared Hemoccult Sensa alone or in combination with a FIT (FlexSure OBT) to evaluate the test characteristics for identifying left-sided cancers and adenomas. Hemoccult Sensa had the highest test positivity rate (10 percent) with possible lower sensitivity for left-sided CRC than FIT alone (64.3 percent sensitivity compared with 81.8 percent, estimates not statistically different) and clearly lower specificity for left-sided CRC (90.1 percent compared with 96.9 percent). A combination Hemoccult Sensa/FlexSure screening approach, where the FIT was developed only if the guaiac-based test was positive, had identical sensitivity and better specificity than Hemoccult Sensa alone (98.1 percent compared with 90.1 percent). Absolute sensitivity or specificity for whole-colon CRC cannot be inferred from these estimates, although the authors' provision of estimates for left-sided lesions are reliable.

Immunochemical tests. Magstream and related tests (HemeSelect) (3 studies). Morikawa recently reported a retrospective analysis of 21,805 asymptomatic adults participating in a Japanese comprehensive health examination program (including colonoscopy) from 1983 to 2002. The study also tested a single stool collection with Magstream 1000 system (a nonFDA approved FIT with an automated reader using a test related to HemeSelect). ^163^ Most (72 percent) participants were male, with ages ranging from 21 to 90 years, and a mean age of 48.2 (+/- 9) years; 18.8 percent were under age 40 years. Invasive cancers were present in 79 patients (0.4 percent), high-grade dysplastic lesions in 119 (0.5 percent) and large adenomas (10 mm or greater) in 529 (2.4 percent). The overall test-positive rate was 5.6 percent using the standard cut-point of 20 ng/ml for hemoglobin. Sensitivity for invasive cancer was 65.8 percent and specificity was 94.6 percent. Sensitivity for any advanced neoplasia was 27.1 percent (compared with 10.4 percent for any neoplasia which also included 10 mm or larger adenoma). Specificity was about the same (95.1 percent to 95.5 percent) for both of these categories. Given the accumulation of cases over 10 years in a health examination program, it is not clear whether the same FIT was used during this entire time period.

Launoy and colleagues evaluated quantitative screening test results using the Magstream 1000 system in 7421 average-risk French patients aged 50–74 (57 percent female). Physicians invited their patients to participant in a 2-day fecal sampling for a CRC screening program during a regular office visit between January 2001 and December 2003. ^166^ Two higher cut-points (>50 ng/ml and >75 ng/ml) were evaluated in addition to the usual cut-point (>20 ng/ml hemoglobin). In all participants, 28 CRC were detected, 22 at colonoscopy, 2 in test-positive patients who did not undergo colonoscopy, and four during 2-year followup of screen-negative participants; 181 adenomas were detected in 366 people undergoing colonoscopy (102 adenomas larger than 10 mm). Test positivity for Magstream was 5.8 percent (cut-point >20 ng/ml), 3.1 percent (cut-point >50 ng/ml), or 2.0 percent (cut-point >75ng/ml). At 2 years, sensitivity for CRC was 85 percent, specificity was 94 percent and PPV was six percent. At higher cut-points (50 or 75 ng/ml), sensitivity for CRC was substantially lower (68 and 61 percent respectively), with three to four percent improvement in specificity to 97 to 98 percent and similar improvement in PPV (nine to 13 percent).

In the same large managed care study that evaluated Hemoccult Sensa, ^160^ HemeSelect tests were also evaluated. A major issue with HemeSelect was the relatively poor test completion rates (62 percent of HemeSelect tests had adequate samples for test completion compared with 91–93 percent of Hemoccult II or Hemoccult Sensa tests). The sensitivity of HemeSelect for CRC was not statistically significantly better than for non-rehydrated Hemoccult II, although specificity was lower (94.4 vs. 97.7).

Monohaem FIT (2 studies). Nakama et.al. calculated the sensitivity and specificity of the Monohaem FIT using samples from three consecutive days, without dietary or medication restrictions, prior to colonoscopy in 4611 Japanese persons aged 40 years and older who were participating in a colorectal cancer checkup. ^169^ Although patients were reported as asymptomatic, nothing further was reported about their risk status (e.g., sex, age distribution, or family history). Eighteen patients had CRC (0.4 percent) and 73 had an adenoma or other colorectal disease (1.6 percent). Overall test-positive rate was not reported. Sensitivity for cancer and adenomas increased significantly with a 2- or 3-day collection sample compared with a single day sample. Similarly, specificity also decreased with greater days of sample collection. With 2 days of samples (optimal approach), sensitivity for cancer was 83.3 percent and for adenomas was 50.7 percent, and specificity was 96.0 percent.

In a separate study in rural Japan, Nakama screened 3365 mainly asymptomatic males and females 40 years and older using a single stool sample for Monohaem screening. ^167^ Test positive adults (4.7 percent) received colonoscopy while test negatives were followed through a cancer registry for up to three years. In all participants, there were 14 cases of CRC; 43 polyps were detected in the 157 persons undergoing colonoscopy. Sensitivity of Monohaem for CRC decreased with followup from 91 percent in the first year to 71 percent in the third year, due to the identification of false-negative cancers, specificity was 95.6 percent.

OC-Hemodia (4 studies). Separate investigative teams reported on the sensitivity and specificity of OC-Hemodia (using an unspecified number of collection days) in 7411 asymptomatic Taiwanese men and women participating in a health checkup (that included colonoscopy) between 1997 and 2000. ^161,^ ^168^ One study ^168^ appears to be a sub-study (n=1387) of those that received esophagogastroscopy and colonoscopy from the same screening population as the other study ^161^ and is not discussed further. The prevalence of cancer was 0.2 percent (16 cancers), advanced neoplasia was 1.3 percent (93 lesions), and polyps was 9.7 percent (719 polyps). The overall test-positive rate was 9.2 percent. Sensitivity for cancer was 87.5 percent, specificity for cancer was 91.0 percent. Sensitivity was lower for any advanced neoplasm (including CRC) at 48.2 percent. OC-Hemodia is not FDA approved or apparently available in the U.S. market.

A study in 27,860 Japanese workers participating in a corporate screening program evaluated OC-Hemodia by sending screen positive patients only to have a colonoscopic exam and following the screen negative patients through insurance claim data for 2 yrs. ^165^ The study employed a 2-day sampling approach that resulted in a test positive rate of 5.3 percent and estimated sensitivity for CRC to be 86.5% and specificity to be 94.9%.

A third study conducted in Israel performed colonoscopy on all participants regardless of FIT results, but only a small subgroup (n=80) were considered average-risk. ^162^ Sensitivity was estimated to be 66.7 percent (CI: 13.3, 120) and specificity was 83.1 percent (CI: 74.7, 91.5). These numbers are imprecise due to the small number of participants within this subgroup.

FlexSure OBT (now Hemoccult ICT) (1 study). A single good-quality prospective study in 5841 screening patients aged 50 and older (26 percent nonWhite, 53 percent female, 11 percent aged 70 years and older) evaluated FlexSure OBT (now Hemoccult ICT) and sequential screening using Hemoccult Sensa followed by FlexSure OBT for positives only in a real-world managed care setting in the US. ^159^ FOBT-positives were sent for colonoscopy and FOBT-negatives were referred for FS (with about 80 percent completion of endoscopy), with 2-year followup for CRC detection as well. Fourteen cancers were detected along with 128 large adenomas. Test positivity was slightly higher for FlexSure (3.2 percent) than the combination (2.1 percent); both were much lower than Hemoccult Sensa alone (10.1 percent). FlexSure had similar (or perhaps better) sensitivity for distal CRC (82 percent) and for large distal adenomas (30 percent) than either other screening approach (power for differences was limited due to small numbers). The combination test had the best specificity for either outcome, with FIT a close second (96.9 percent and 98.1 percent for CRC, respectively). Absolute sensitivity or specificity for whole-colon CRC can not be inferred from these estimates. These estimates for left-sided lesions, however, are reliable.

Table 1 Evidence table of CT colonography studies

Study | Setting | Reference Standard Operator Characteristics CT test characteristics | Inclusion/ Exclusion Criteria | Patient Characteristics | Prevalence and Yield of Polyps | Sensitivity (95% CI) | | | Specificity (95% CI) | | | Positive Predictive Value | Applicability | Comments
Pickhardt 2003 ^136^ Good | Military Medical Centers in Bethesda, MD; Washington, DC; San Diego, CA Recruited consecutive patients who were primarily referred for screening colonoscopy | OC with segmental unblinding Same day CTC and OC. Performed by 1/17 experienced colonoscopists 1 of 6 board-certified radiologists prospectively reviewed the CT data. All had completed training and read at least 25 studies. Two had interpreted more than 100. Flythrough 3D with 2D correlation of any abnormality; 1.25–2.5 mm collimation; 1 mm reconstruction interval; Multidetector; Oral contrast; Viatronix V3D 1.2 | Inclusion: Adults 50–79 yrs of average risk; 40–79 yrs with family history of CRC Exclusion: positive guaiac-based stool test within 6 mo of referral; iron-deficiency anemia within 6 mo; rectal bleeding or hematochezia within 12 mo; unintentional weight loss > 10 lbs within 12 mo; optical colonoscopy within 10 yrs; BE within 5 yrs; history of adenomatous polyps, CRC or IBD; history of familial adenomatous polyposis or hereditary non polyposis cancer syndromes; rejection for optical colonoscopy; medical condition that precludes use of sodium phosphate prep; pregnancy. | N: 1233 Mean age: 57.8 yrs Female: 41% Race/Ethnicity: NR SES: NR Average risk: 97.4% (1201/1233) Family history: 2.6% (32/1233) | [underlined: Prevalence] ≥ 10 mm: 3.9% ≥ 8 mm: 6.7% ≥ 6 mm: 13.6% [underlined: Yield] Any size polyp: Adenomatous 554 Nonadenomatous 756 ≤ 5 mm: Adenomatous 344 Nonadenomatous 622 6–9 mm: Adenomatous 159 Nonadenomatous 103 ≥ 10 mm: Adenomatous 51 Nonadenomatous 31 | [underlined: Of adenomas per patient] ≥ 6: 88.7 (82.9, 93.1) ≥ 7: 90.9 (83.9, 95.6) ≥ 8: 93.9 (86.3, 98.0) ≥ 9: 93.0 (83.0, 98.1) ≥ 10: 93.8 (82.8, 98.7) [underlined: Of adenomas per polyp] ≥ 6: 85.7 (80.2, 90.1) ≥ 7: 89.5 (83.0, 94.1) ≥ 8: 92.6 (85.4, 97.0) ≥ 9: 91.8 (81.2, 97.3) ≥ 10: 92.2 (81.1, 97.8) | | | [underlined: Of adenomas per patient] ≥ 6: 79.6 (77.0, 82.0) ≥ 7: 87.4 (85.3, 89.2) ≥ 8: 92.2 (90.5, 93.7) ≥ 9: 94.9 (93.5, 96.1) ≥ 10: 96.0 (94.8, 97.1) | | | [underlined: PPV] Of adenomas per patient ≥ 6: 40.7% ≥ 7: 41.3% ≥ 8: 46.1% ≥ 9: 46.9% ≥ 10: 48.9% (Calculated) [underlined: NPV] Of adenomas per patient ≥ 6: 97.8% ≥ 7: 99.0% ≥ 8: 99.5% ≥ 9: 99.6% ≥ 10: 99.7% (Calculated) | Uses rigorous methods that are unlikely to be found in general practice (type of bowel prep, stool tagging, electronic fluid cleansing). Screening conducted at military medical centers. Large sample size that includes 41% women. Ethnic diversity unknown. | Incomplete optical colonoscopy: 0.6% (8/1253) Inadequate preparation: 0.5% (6/1253) Failure of CT colographic system: 0.5% (6/1253)
Pickhardt 2004 ^152^ | Flat lesions: Secondary analysis of Pickhardt 2003 data | | | | [underlined: Prevalence of flat polyps] Persons: 4.2% (52/1233) [underlined: Yield of flat lesions] 59 of 344 total polyps identified (17.2%) [underlined: Adenomatous flat lesions] 29/59 (49.2%) [underlined: Adenomatous flat lesions of all adenomas identified] 29/210 (13.8%) | [underlined: To detect adenomatous flat lesions] 82.8% (vs 86.2% non-flat adenomas, p=0.58 for difference)
Pickhardt 2007 ^151^ | Re-analysis of 730 cases utilizing 2D analysis by more experienced CTC readers than in the original trial. Compared against original 1233 cases in primary 3D review. | | | | | [underlined: By-patient] Adenoma ≥ 10mm: 2D 81% (25/31) 3D 94% (45/48) ≥ 6 mm: 2D 49% (51/105) 3D 89%(149/168) Polyps ≥ 10mm: 2D 63%(26/41) 3D 86% (62/72) ≥ 6 mm: 2D 43% (64/149) 3D 84% (214/255) | | | [underlined: By-patient] Polyps ≥ 10mm: 2D 98% (676/689) 3D 97% (1131/1161) ≥ 6 mm: 2D 95% (553/581) 3D 85% (826/978)
Macari 2004 ^149^ Fair-to-Poor | Veterans Affairs Hospital in New York. Recruited from gastro clinic | OC with no unblinding during procedure to verify finding on CT that were not seen during CTC Same day CTC and OC. Performed by a gastroenterologist with 5 yrs experience or fellow under supervision of the gastroenterologist. 2D with 3D confirmation of any abnormality; 4×1 mm collimation; 1 mm reconstruction interval; Multidetector; No contrast; Vitrea 2 | Inclusion: Those attending a gastroenterology clinic and scheduled to undergo a screening colonoscopy; > 50 yrs; no colorectal symptoms; had negative FOBT; no family history of CRC in first-degree relative. Exclusion: NR | N: 68 Mean age: 55 yrs Female: 0% Race/Ethnicity: NR SES: NR Average risk: 100% | [underlined: Prevalence] Any polyp: 57% (39/68 patients) Largest polyp 1–5 mm: 23 patients 6–9 mm: 13 ≥ 10 mm: 3 Yield 1–5 mm: 78 6–9 mm: 17 ≥ 10 mm: 3 | Per polyp Any size: 21.4 (14.2, 31.1) 1–5 mm: 11.5 (5.4, 23.3) 6–9 mm: 52.9 (29.1, 75.5) ≥ 10 mm: 100 (36.8, 100) | | | Per patient Any size: 89.7 (72.7, 97.8) ≥ 10: 98.5 (91.7, 99.9) | | | NR | 100% male population seen in a VA medical center. Small sample size. All had negative FOBT results and no prior history. | False positives of CT were not verified during colonoscopy, rather assumed to be residual fecal material. No per patient sensitivity, only per polyp.
Macari 2000 ^148^ Fair | New York City Patient recruitment: NR | OC with no unblinding during procedure to verify findings on CT that were not seen during colonoscopy Same day CT colonography and optical colonoscopy. Method 1: 2D with 3D on abnormal areas. Method 2: 2D then 3D Two radiologists with training in CTC examined each data set with different methods. 2D and 3D; 5 mm collimation; 2.5 mm reconstruction interval; Single detector; No contrast; Advantage/Navigator | Inclusion: Patients scheduled for colonoscopy screening. Exclusion: < 18yrs; pregnancy; patients with IBD, CRC, polyps, or polyposis. | N: 42 Mean age: 56 yrs Female: 45% Race/Ethnicity: NR SES: NR Asymptomatic: 100% Family history: 29% | [underlined: Prevalence] Any polyp: 31% (13/42) [underlined: Yield] 1–5 mm: 10 6–9 mm: 5 >10 mm: 1 | [underlined: Method 1-per polyp] 38% [underlined: Method 2-per polyp] 38% [underlined: For polyps ≥ 6 mm] 67% [underlined: For polyps ≥ 7 mm] 100% | | | [underlined: Method 1-per polyp] 100% [underlined: Method 2-per polyp] 96% | | | [underlined: Method 1-per polyp] 100% [underlined: Method 2-per polyp] 86% NPV [underlined: Method 1-per polyp] 73% [underlined: Method 2-per polyp] 72% | Patient recruitment to University medical center unknown. Population included 45% women, but the ethnic distribution is unknown. Small sample size. | 2 false positives in one patient were attributed to residual stool.
Rex 1999 ^150^ Fair/Poor | Veterans Affairs Hospital in Indianapolis | OC with no unblinding during procedure. Findings indicated on CTC, but not found during optical colonoscopy were reviewed on the colonoscopy video. Same day CTC and OC 2D and 3D; 5 mm collimation; 2 mm reconstruction interval; Single detector; No contrast; Bowman Gray Virtual Endoscopy (Free Flight) | Inclusion: Without symptoms; no history of colon polyps or CRC. Intentionally selected older and male patients to increase polyp prevalence. Exclusion: NR | N: 46 Mean age: 67.7 yrs Female: 2% Race/Ethnicity: NR SES: NR Never undergone colon exam: 63% Polyps detected on screening flex sig: 37% | [underlined: Prevalence of adenoma] 72% (33/46), which included 14/17 patients with polyps detected on FS. [underlined: Yield] All adenomas: 91 ≤ 5 mm: 63 6–9 mm: 14 10–19 mm: 10 ≥ 20 mm: 4 | [underlined: Per patient] 2D ≤ 5 mm: 19% 6–9 mm: 14% 10–19 mm: 67% ≥ 20 mm: 75% 3D ≤ 5 mm: 25% 6–9 mm: 43% 10–19 mm: 83% ≥ 20 mm: 75% [underlined: By polyp] 2D ≤ 5 mm: 8% 6–9 mm: 7% 10–19 mm: 30% ≥ 20 mm: 25% 3D ≤ 5 mm: 11% 6–9 mm: 43% 10–19 mm: 60% ≥ 20 mm: 25% | | | Per patient in adenomas ≥ 10 mm 89% | | | NR | Poor. 98% male (67.7 yrs) population at a VA medical center who were intentionally selected to oversample older males to yield a high prevalence of polyps. | Flat adenomas were hard to identify. 3/4 >2.0 mm were flat adenomas and missed by CT. Included a FS + sample to increase polyp yield. Population was also intentionally selected to be male and > 60 yrs to increase polyp prevalence. Missed polyps on CT were due to: residual stool and water; collapsed segments; missed by reader. None of the positives found by CT, but not colonoscopy were found on visual inspection of the videos and were classified as false positives.
Johnson 2007 ^138^ Fair | Mayo Clinic, MN. Comparison of primary 2D and 3D interpretation and slice thickness of 1.25 vs. 2.5mm. 3D software allows for 360 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | OC Same day CTC and OC Three radiologists who all had > 1000 colonoscopy-verified CT colonography examinations. 6 weeks between the two readings of an exam by the same reader. Performed by staff gastroenterologists or supervised by staff gastroenterologists and colorectal surgeons 1.25 and 2.5 mm collimation; 1.25 mm reconstruction interval; Multi detector; No contrast; Voxtool 5.4.46, GE Healthcare | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | [underlined: Per-Patient 1.25 mm; ≥ 10mm] | | | [underlined: Per-Patient 1.25 mm; ≥ 10mm] | | | | Asymptomatic population but did include persons with previous colonic resection | Study initiated prior to standard tagging procedures and mechanical insufflation that are commonly used in clinical practice today. Limited power due to multiple analyses and not primarily addressing overall accuracy.
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 2D | | 3D | 2D | | 3D | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 1 83%(5/6) | | 50%(4/8) | 1 99%(134/135) | | 97%(134/138) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 2 70%(7/10) | | 83%(5/6) | 2 98%(137/140) | | 99%(142/144) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 3 78%(7/9) | | 83%(10/12) | 3 97%(143/147) | | 97%(137/141) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 2D & 3D Review: | | 95%(18/19) | 2D & 3D Review: | | 98%(205/210) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | [underlined: Per-Patient 1.25 mm; 6–9mm] | | | [underlined: Per-Patient 1.25 mm; 6–9mm] | | | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 2D | | 3D | 2D | | 3D | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 1 40%(4/10) | | 33%(4/12) | 1 92%(120/131) | | 93%(125/134) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 2 25%(2/8) | | 60%(6/10) | 2 99%(140/142) | | 96%(134/140) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 3 83%(10/12) | | 100%(8/8) | 3 95%(137/144) | | 94%(136/145) | | Asymptomatic population but did include persons with previous colonic resection
Johnson 2007 ^138^ Fair | | | Inclusion: NR Exclusion: melena; hematochezia; IBD; familial polpyposis; symptomatic. | N: 452 Mean age: 65 yrs (41–82) Female: 44% Race/Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR Asymptomatic: 100% | [underlined: Prevalence at least 1 adenomatous lesion] ≥ 10 mm: 5.8% (26/452) 6–9 mm: 6.6% (30/452) [underlined: Yield] Adenoma ≥ 10 mm: 26 Adenoma 6–9 mm: 38 | 2D & 3D Review: | | 71%(10/14) | 2D & 3D Review: | | 91%(196/215) | | Asymptomatic population but did include persons with previous colonic resection
Per lesion sensitivity of colonoscopy for lesions ≥ 10mm: 77%
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | OC with segmental unblinding Same day CTC and OC 2 radiologists with 300 and 500 previous CTC examinations who did not participate in the original analysis of this data. Two months separated the 2D and 3D viewings. Colonoscopy was performed by 1/5 experienced gastroenterologists 2D and 3D; 2 mm collimation; 1 mm reconstruction interval; Multi detector; IV contrast; 2D software: Rapidia; 3D software: Perspective Filet View | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | [underlined: Per patient] | | | [underlined: Per patient] | | | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | Reader | 1 | 2 | Reader | 1 | 2 | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | | | | | | | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | ≥ 6 mm | | | ≥ 6 mm | | | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | 2D | 64%(14/22) | 59%(13/22) | 2D | 91%(67/74) | 89%(66/74) | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | 3D | 77%(17/22) | 73%(16/22) | 3D | 99%(73/74) | 89%(66/74) | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | ≥ 8 mm | | | ≥ 8 mm | | | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | 2D | 92%(12/13) | 92%(12/13) | 2D | 98%(81/83) | 99%(82/83) | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | 3D | 85%(11/13) | 92%(12/13) | 3D | 99%(82/83) | 98%(81/83) | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation 3D software allows for 380 degree panoramic display with virtual unfolding and dissecting of the colon along the longitudinal axis. | | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficient anemia; +FOBT within 6 mo; < 40 yrs; history of familial adenomatous polyposis; polypectomy within 1 yr. | N: 96 Mean age: 54.8 yrs Female: 42% Race/Ethnicity: Asian 100% (assumed) SES: NR | [underlined: Yield] Polyp ≥ 10 mm: 12 Polyp 6–9 mm: 23 Polyp < 5 mm: 99 Advanced neoplasia: 9 | ≥ 10 mm | | | ≥ 10 mm | | | | Unknown. Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is also unknown. | Reasons for false-negatives: flat lesions; poor bowel distention; close attachment to a fold; misinterpreted as feces.
2D | 100%(9/9) | 100%(9/9) | 2D | 99%(86/87) | 100%(87/87)
3D | 100%(9/9) | 100%(9/9) | 3D | 100%(87/87) | 99%(86/87)

Table 2 Evidence table of trials testing high sensitivity guaiac tests, fecal immunochemical tests, fecal DNA

Author, Year | Primary Screening Test Evaluated | Setting | Reference/Gold Standard | Methods of FOBT collection | Inclusion/Exclusion Criteria | Patient Characteristics: | Prevalence and Yield of Polyps | Test completion rate Test positivity rate | Sensitivity (95% CI) | Specificity (95% CI) | Positive Predictive Value | Negative Predictive Value | Applicability | Comments
Nakama 1999 ^169^ Fair | Monohaem | Japan Asymptomatic adults participating in colorectal cancer check-up. | Colonoscopy 100% | 3 consecutive days of collection without dietary or medicinal restrictions prior to colonoscopy. | Inclusion: Attending colonoscopy medical check-up; over 40 yrs. Exclusion: NR | N: 4611 Age: NR Female: NR Ethnicity: NR SES: NR | Colorectal cancer: 18 patients (0.4%) Adenomatous polyp or other colorectal diseases: 73 patients (1.6%) | Test completion rate NR Test positivity rate NR | 1-day collection Cancer: 55.6%* Adenoma: 30.1%* 2-day collection Cancer: 83.3% Adenoma: 50.7% 3-day collection Cancer: 88.9% Adenoma: 54.8% *p<0.01 difference from 2- and 3-day | 1-day collection 97.1% 2-day collection 96.0% 3-day collection 93.9%** **p<0.05 difference from 1- and 2-day | 1-day collection Cancer: 6.1% CRC or adenoma: 19.6% 2-day collection Cancer: 6.5% CRC or adenoma: 22.4% 3-day collection Cancer: 4.8% CRC or adenoma: 16.9% | NR | Japanese population with unknown population characteristics-not clearly average risk. Its applicability to the US population is unknown.
Morikawa 2005 ^163^ 2007 ^340^ Fair | Magstream | Japan Retrospective analysis of consecutive asymptomatic adults participating in comprehensive health examination program 1983-2002. | Colonoscopy 100% | 1-time collection | Inclusion: Asymptomatic and voluntarily participated. Exclusion: Patients with reported symptoms of disease of lower gastrointestinal tract | N: 21,805 Age: 48.2 ± 9.3 yrs Range (21–90 yrs) <40 yrs (18.8%) Female: 28% Ethnicity: NR SES: NR | Prevalence Invasive cancer: 79 pts (0.4%) High-grade dysplasia: 119 pts (0.5%) Adenoma ≥ 10 mm: 529 (2.4%) Adenoma ≤ 9 mm: 3615 (16.6%) | Test completion rate NR Test positivity rate 5.6% (1231/21,805) | Advanced neoplasia: 27.1% (23.9–30.3) Invasive cancer: 65.8% (55.4–76.3) High-grade dysplasia: 32.7% (24.3–41.2) Adenoma ≥ 10 mm: 20.0% (16.6–23.4) Neoplasia: 10.4 (9.5–11.3) Adenoma ≤ 9 mm : 7.0% | Advanced neoplasia: 95.1% (94.8–95.4) Invasive cancer: 94.6% (94.3–94.9) Neoplasia: 95.5% (95.2–95.8) Adenoma ≤ 9 mm : 95.5% | Advanced neoplasia: 16.0% Invasive cancer: 4.2% Neoplasia: 36.5% (calc) | Neoplasia : 81.2% (calc) | Japanese population that appears to be primary care and community-based setting. Unknown applicability to US population. | Retrospective analysis beginning in 1982.
Allison2007 ^159^ Good | Flex-Sure OBT; Hemoccult Sensa | US Prospective analysis of asymptomatic, average-risk patients within a large HMO. April 1997–October1999. | Colonoscopy to those with +FOBT; Flexible sigmoidoscopy to -FOBT. 2 year follow-up in medical databases. | 3-sample collection with vitamin C restriction for 3 days before and during collection. | Inclusion: HMO members; ≥ 50 yrs. Exclusion: IBD; active rectal bleeding; +FOBT within 12 months; history of colon cancer or polyps; colonoscopy or FS within 5 yrs; family history of colon cancer with either a single affected first-degree relative ≥ 55 yrs or ≥ 2 of any age; any barrier to understanding the consent form. | N: 5841 had at least one valid FOBT Age: 50–59 58.7% 60–69 30.4% ≥ 70 10.9% Female: 52.5% Ethnicity: White 74.1% Black 5.0% Asian 11.8% Hispanic 5.2% Other 3.9% SES: NR | Prevalence of left-sided neoplasms in those attending FS or colonoscopy Cancer: 14 (0.3%) Adenoma ≥ 10 mm: 128 (2.7%) | Test completion rate FlexSure: 97.7% HOSensa: 97.8% Test positivity rate FlexSure: 3.2% HOSensa: 10.1% Combination: 2.1% | Distal cancer FlexSure: 81.8 (47.8 – 96.8) HOSensa: 64.3 (35.6 – 86.0) Combination: 64.3 (35.6 – 86.0) Distal adenoma ≥ 10 mm FlexSure: 29.5 (21.4 – 38.9) HOSensa: 41.3 (32.7 – 50.4) Combination: 22.8 (16.1 – 31.3) | Distal cancer FlexSure: 96.9 (96.4 – 97.4) HOSensa: 90.1 (89.3 – 90.8) Combination: 98.1 (97.7 – 98.4) Distal adenoma ≥ 10 mm FlexSure: 97.3 (96.8 – 97.7) HOSensa: 90.6 (89.8 – 91.4) Combination: 98.4 (98.0 – 98.7) | Distal cancer FlexSure: 5.2 (2.6 – 10.0) HOSensa: 1.5 (0.8 – 3.0) Combination: 7.4 (3.7 – 14.0) Distal adenoma ≥ 10 mm FlexSure: 19.1 (13.7 – 25.9) HOSensa: 8.9 (6.8 – 11.6) Combination: 24.0 (16.9 – 32.7) | NR | High applicability as drawn from an average-risk US population. 74% were Caucasian. Only considered left-sided lesions.
Cheng 2002 ^161^ Fair | OC-Hemodia | Taiwan Participants in a health screening program from January 1997–December 2000. | Colonoscopy 98.9% | 3-day dietary restriction | Inclusion: Asymptomatic participants in health screening program and voluntarily participated. Those with history of polyps or family history were included. Exclusion: Incomplete colon examination; presence of related symptoms; history of CRC, colitis, of IBD; previous +FOBT; location or size of lesion not defined or not pathologic examination. | N:7411 Age: 46.8 ± 9.9 yrs >50 yrs 31.25% 41–50 41.51% Female: 44.8% (calc) Ethnicity: NR SES: NR | Prevalence Polyps: 719 (9.7%) Advanced neoplasm: 93 (1.3%) Cancer: 16 (0.2%) | Test completion rate NR Test positivity rate Overall: 9.2% | All polyps 16.8% (calc) Advanced neoplasm 48.4% (calc) Cancer 87.5% (calc) | All polyps 91.6% (calc) Advanced neoplasm 91.3% (calc) Cancer 91.0% (calc) | All polyps 17.7% (calc) Advanced neoplasm 6.6% (calc) Cancer 2.0% (calc) | All polyps 91.1% (calc) | Applicability of Taiwanese population to US is unknown. This is also a fairly young population as 41% are <50 and 28% <40 yrs. Population appears to be fairly representative of an asymptomatic, primary care population. | Prevalence Polyps: 719 (9.7%) Advanced neoplasm: 93 (1.3%) Cancer: 16 (0.2%)
Levi 2007 ^162^ Fair | OC-Micro (OC-Hemodia) | Israel | Colonoscopy 100% | 3-day collection No dietary restrictions; stopping aspirin and anticoagulants prior to endoscopy | Inclusion: Referred for colonoscopy. Exclusion: Concurrent hospitalization; visible rectal bleeding; IBD; hematuria; menstruation at time of stool specimen; inability to prepare FIT | N: 1000 Analyzing subset with family history (N=80) Age: NR for subgroup Female: NR for subgroup Ethnicity: NR SES: NR | Prevalence Colorectal cancer: 3 (3.8%) Advanced polyps (≥ 10 mm; ≥ 20% villous histologic characteristics; high-grade dysplasia) | Test completion rate NR Test positivity rate Overall: 18.8% in subset (calc) | FAMILY HISTORY ONLY Advanced neoplasm 55.6 (32.6 – 78.5)% Cancer 66.7 (13.3 – 120)% | FAMILY HISTORY ONLY Advanced neoplasm 91.9 (85.2 – 98.7)% Cancer 83.1 (74.7 – 91.5)% | | | Small numbers in this subgroup.
Launoy 2005 ^166^ Fair | Magstream | France Patients aged 50–74 yrs attending a regular consultation with their physician were invited to participate. January 2001–December 2002. | 366 of 434 screen+ pts attended colonoscopy Screen negative patients were followed through cancer registry January 2001–December 2003. | 2 samples on different days with no dietary restrictions. | Inclusion: 50–74 yrs attending primary care physician. Exclusion: NR | N: 7421 Age: 50–54 20.9% 55–59 20.3% 60–64 19.8% 65–69 22.1% 70–74 16.8% Female: 57% Ethnicity: NR SES: NR | Prevalence in those attending colonoscopy (iFOBT+) (n=366) CRC: 22 (6%) Adenoma ≥ 1 cm: 102 (27.9%) Adenoma ≥ 1 cm: 79 (21.6%) Prevalence in those not attending colonoscopy(n=68) CRC: 2 within 2 years of + screen Prevalence detected through cancer registry in those screening negative (n=6987) CRC: 4 (0.06%) | Test completion rate NR Test positivity rate > 20 ng/ml: 5.8% > 50 ng/ml: 3.1% > 75 ng/ml: 2.0% | At 2 years follow-up > 20 ng/ml: 0.85 (0.72–0.98) > 50 ng/ml: 0.68 > 75 ng/ml: 0.61 | At 2 years follow-up > 20 ng/ml: 0.94 (0.94–0.95) > 50 ng/ml: 0.97 > 75 ng/ml: 0.98 | For CRC > 20 ng/ml: 0.06 > 50 ng/ml: 0.09 > 75 ng/ml: 0.13 For Adenoma ≥ 1 cm > 20 ng/ml: 0.28 > 50 ng/ml: 0.40 > 75 ng/ml: 0.41 | NR | French primary care population of unknown racial breakdown. The false negatives are likely to be underestimated by the cancer registry follow-up, falsely elevating the sensitivity.
Itoh 1996 ^165^ Fair | OC-Hemodia | Japan Patients 40 or older who worked for corporations participating in colorectal screening program were invited during 1991-1992. | Colonoscopies were offered to those who screened positive: 1207/1490 (81% compliance). Those screening negative were followed through a cancer registry and re-screened at 2 yrs. | 1 time sample | Inclusion: Aged 40 and above; employee of corporations that take part in program Exclusion: NR | N: 27,860 Age: NR Female: 14% (calc) Ethnicity: NR SES: NR | Prevalence in those attending for colonoscopy CRC: 77/1207 (6.4%) Prevalence detected through cancer registry in those screening negative CRC: 12/26370 (0.05%) | Test completion rate 84.3% Test positivity rate Overall: 5.3% Those with CRC: 86.5% | For CRC: 86.5% | For CRC: 94.9% | For CRC: 5.2% | NR | Applicability of Japanese population to US is unknown. The population is asymptomatic, but age is not reported. Women are underrepresented. The false negatives are likely to be underestimated by the shorter term cancer registry follow-up, falsely elevating the sensitivity.
Nakama 1996 ^167^ Fair | Monohaem | Japan-rural Mainly asymptomatic patients > 40 yrs. | Colonoscopies were offered to those who screened positive-100% compliance with 2% receiving barium enema) All screened were followed through a cancer registry for up to 3 yrs. | 1 time sample without dietary restrictions | Inclusion: NR Exclusion: those who had already been screened. | N: 3365 Age: 40–49 21% 50–59 24% 60–69 31% 70–79 23% 80+ 0.4% Female: 51% (calc) Ethnicity: NR SES: NR | Prevalence in those attending for colonoscopy (n=157) CRC: 10 (6.4%) Polyps: 43 (27.4%) Prevalence detected through cancer registry in those screening negative (n=3,208) CRC: 4 (0.12%) | Test completion rate 84.5% Test positivity rate Overall: 4.7% | For CRC: First yr 90.9% Second yr 83.3% Third yr 71.4% | For CRC 95.6% | 6.4% | NR | Applicability of a rural Japanese population is unknown. The population is asymptomatic and of varied ages. The false negatives are likely to be underestimated by the shorter term cancer registry follow-up, falsely elevating the sensitivity.
Allison 1996 ^160^ | Hemoccult Sensa; HemeSelect; Nonrehydrated Hemmoccult II | Oakland, CA Patients > 50 yrs attending health appraisal at Kaiser Permanente (October 1990–October 1991). | Colonoscopy or FS FS was suggested for those with only + Hemoccult Sensa due to high FP rate during initial part of study. Those with neoplasm on FS or with Hemocult Sensa positive on repeating testing at 6 and 12 months or if preferred colonoscopy over FS were referred for colonoscopy. Follow-up information obtained from participants' medical records, cancer registry, and pathology files. | 3 consecutive stool samples for each FOBT Advised to restrict vitamin C, aspirin or NSAIDs, and follow dietary restrictions. | Inclusion: > 50 yrs attending health appraisal. Exclusion: NR | [underlined: Total Study Population] N: 8,104 Age: 50–59 30.2% 60–69 39.0% ≥ 70 30.8% Female: 59.3% Ethnicity: Non-white 46.5% SES: NR 1312 FOBT+ | Prevalence CRC: 35 Benign polyps: 107 | Test completion Hemocult Sensa: 91.4% HemeSelect: 62.2% Hemoccult Sensa and HemeSelect: ≤ 62.2% Hemoccult II: 93.5% Test positivity rates-Criteria ≥ 1 window positive Hemocult Sensa: 13.6% HemeSelect: 5.9% Hemoccult Sensa and HemeSelect: 3.0% Hemoccult II: 2.5% | CRC Hemocult Sensa: 79.4%(64.3–94.5) HemeSelect: 68.8%(51.1–86.4) Hemoccult Sensa and HemeSelect: 65.6%(47.6–83.6) Hemoccult II: 37.1%(19.7–54.6) | CRC Hemocult Sensa: 86.7%(85.9–87.4) HemeSelect: 94.4%(93.8–94.9) Hemoccult Sensa and HemeSelect: 97.3%(96.9–97.6) Hemoccult II: 97.7%(97.3–98.0) | Carcinoma Hemoccult II Sensa: 2.5%(1.7–3.7) HemeSelect: 5.0%(3.2–7.6) Hemocult Sensa and HemeSelect: 9.0%(5.8–13.6) Hemoccult II: 6.6%(3.7–11.2) Polyp ≥ 10 mm Hemoccult II Sensa: 6.7%(5.3–8.4) HemeSelect: 15.5%(12.3–19.3) Hemocult Sensa and HemeSelect: 21.9%(16.9–27.9) Hemoccult II: 16.7%(11.9–22.8) Carcinoma or polyp Hemoccult II Sensa: 9.2%(7.6–11.2) HemeSelect: 20.5%(16.8–24.6) Hemocult Sensa and HemeSelect: 30.9%(25.1–37.3) Hemoccult II: 23.2%(17.7–29.9) | NA | Good. Sample is U.S. primary care population with minority representation. Colonoscopies or FS with follow-up Hemoccult II as an alternative “gold standard” were given only to those screening positive with medical record follow-up of the screen negative patients to address FN. | Used 2 yr medical record follow-up to determine TN and FN, which is inadequate for determination of polyps. Used only for CRC and is generally an overestimate of sensitivity compared to 100% colonoscopy. Test performance doesn't consider smaller lesion (< 10 mm).
Imperiale 2004 ^158^ | Fecal DNA panel (K-ras; p53; APC; BAT-26; Long DNA) Hemoccult-non-rehydrated | US 81 sites including private practice and university based settings. Asymptomatic adults ≥ 50 yrs of average risk. August 2001–March 2003. | Colonoscopy | Fecal DNA panel-1 sample Hemoccult II-3 samples No dietary or medication modifications. | Inclusion: At least 50 yrs Exclusion: Gastrointestinal bleeding within preceding month; a change in bowel habits or recent onset of abdominal pain; previous colorectal cancer or polyps; prior resection of any part of the colon; iron-deficiency anemia; other visceral cancer; undergone colonoscopy, FS, or BE within preceding 10 yrs; +FOBT test within preceding 6 months; IBD, familial adenomatous polyposis or hereditary nonpoluposis colon cancer; ≥ 1 first degree relative with CRC or any first degree relative with CRC before 50 yrs. | N: 2507 for sens/spec calculations: 33-carcinoma 403-advanced adenomas 648-minor polyps (random subsample) 1423-no polyps (random subsample) Age: 69.5 yrs Female: 55.5% Ethnicity: Non-white 13% SES: NR | Prevalence Carcinoma: 33/4404 (0.75%) Advanced adenomas: 426/4404 (9.7%) Minor polyps: 1627/4404 (37%) No polyps: 2318/4404 (52.6%) | Test completion rate NR Test positivity rate Fecal DNA:205/2505 (8.2%-calc) Hemoccult II: 146/2505 (5.8%-calc) | CRC Fecal DNA: 51.6% Hemoccult II: 12.9% Advanced adenoma Fecal DNA: 15.1% Hemoccult II: 10.7% | CRC (calculated) Fecal DNA: 92.4% Hemoccult II: 94.3% CRC+ Advanced dysplasia (calculated) Fecal DNA: 92.8% Hemoccult II: 94.4% Advanced adenoma (calculated) Fecal DNA: 93.2% Hemoccult II: 95.1% No polyp Fecal DNA: 94.4% Hemoccult II: 95.2%
Haug 2007{Haug, 2007 5368 /id} | Fecal DNA (K-ras) | Germany Patients were recruited by their primary care physician as part of a general health examination. | Colonoscopy | 1 sample (for group “A”) | Inclusion: Participating in the ESTHER trial. Exclusion: NR | N: 441 Age: NR, but similar to total study population listed below 50–54 16% 55–59 17% 60–64 29% 65–69 24% 70–75 14% Female: 53% Ethnicity: NR SES: NR | Prevalence Advanced neoplasia: 7.0% (31/441) Invasive CRC: 1.6% (7/441) K-ras in patients with negative colonoscopy: 7.5% (22/293) | Test completion rate NR Test positivity rate 26/434 (6.0%-calc) | Advanced colorectal neoplasia 0% (calc) 0/31 | Advanced neoplasia: 95.1% (94.8–95.4) Invasive cancer: 94.6% (94.3–94.9) Neoplasia: 95.5% (95.2–95.8) | | | Self-selecting patient population with delayed time to colonoscopy perhaps affecting results.

## Table 3. Key question 2B excluded studies

### Reference Reason for exclusion

Abdul Fattah A, Nakama H, Kamijo N. Clinico-pathological features of colorectal adenomatous polyps with negative results on immunochemical fecal occult blood test. Eur J Med Res. 1997;2:361-364. Excluded for population. [pmid: 9262491].
Abdul Fattah A, Nakama H, Zhang B, Uehara Y, Kamijo N, Fujimori K. Diagnostic value of immunochemical fecal occult blood test for small colorectal neoplasms. European Journal of Medical Research. 1997;2(5):227-30. Excluded for study design. [pmid: 9153349].
Abe N, Watanabe T, Nakashima M, et al. Quantitative analysis of telomerase activity: a potential diagnostic tool for colorectal carcinoma. Hepatogastroenterology. 2001;48:692-695. Did not include one of the specific screening tests. [pmid: 11462905].
Ahlquist DA, Shuber AP. Stool screening for colorectal cancer: evolution from occult blood to molecular markers. Clinica Chimica Acta. 2002;315:157-168. Not an original study.
Arnesen RB, Adamsen S, Svendsen LB, Raaschou HO, von BE, Hansen OH. Missed lesions and false-positive findings on computed-tomographic colonography: a controlled prospective analysis. Endoscopy. 2005;37:937-944. Excluded for population. [pmid: 16189765].
Arnesen RB, von BE, Adamsen S, Svendsen LB, Raaschou HO, Hansen OH. Diagnostic performance of computed tomography colonography and colonoscopy: a prospective and validated analysis of 231 paired examinations. Acta Radiologica. 2007;48:831-837. Excluded for population. [pmid: 17924213].
Banerjee S, Van Dam J. CT colonography for colon cancer screening. Gastrointest Endosc. 2006;63:121-133. Excluded for study design. [pmid: 16377329].
Barancin C, Roeder B, Cornett D, et al. A retrospective analysis of abnormal findings on virtual colonoscopy compared with optical colonoscopy. Gastroenterology. 2006;130:A643. Excluded for study design.
Belo-Oliveira P, Curvo-Semedo L, Rodrigues H, Belo-Soares P, Caseiro-Alves F. Sigmoid colon perforation at CT colonography secondary to a possible obstructive mechanism: report of a case. Diseases of the Colon & Rectum. 2007;50:1478-1480. Excluded for population. [pmid: 17665253].
Berger BM, Schroy PC III, Rosenberg JL, et al. Colorectal cancer screening using stool DNA analysis in clinical practice: early clinical experience with respect to patient acceptance and colonoscopic follow-up of abnormal tests. Clinical Colorectal Cancer. 2006;5(5):338-43. Excluded for quality. [pmid: 16512992].
Bisseling TM, Dekker HM, Cools B, Nagengast FM. CT colonography to visualise the whole colon can be complementary to incomplete colonoscopy. Netherlands Journal of Medicine. 2006;64(10):389-90. Excluded for study design. [pmid: 17122459].
Blue Cross Blue Shield Association. Fecal DNA Analysis for Colorectal Cancer Screening. 2006. Source document
Blue Cross Blue Shield Association. Immunochemical versus guaiac fecal occult blood tests. 2004. Chicago IL: Blue Cross Blue Shield Association (BCBS). Source document
Blue Cross Blue Shield Association. Special report: fecal DNA analysis for colon cancer screening. Technology Evaluation Center Assessment Program Executive Summary. 2006;21(6):1-2. Excluded for study design.
Blue Cross Blue Shield Association. CT colonography (‘virtual colonoscopy’) for colon cancer screening. 2004. Chicago IL: Blue Cross Blue Shield Association (BCBS). Source document
Bond JH. Progress in refining virtual colonoscopy for colorectal cancer screening. Gastroenterology. 2005;129(6):2103-6. Excluded for study design: Review. [pmid: 16344077].
Booth RA. Minimally invasive biomarkers for detection and staging of colorectal cancer. Cancer Lett. 2007;249(1):87-96. Excluded for study design. [pmid: 17275174].
Brand RE, et al. Reproducibility of a Multitarget Stool-Based DNA Assay for Colorectal Cancer Detection. American Journal of Gastroenterology. 2004;99:1338-1341. Excluded for population with cancer. [pmid: 15233675].
Bruzzi JF, Moss AC, Brennan DD, MacMathuna P, Fenlon HM. Colonic surveillance by CT colonography using axial images only. Eur Radiol. 2004;14:763-767. Excluded for population. [pmid: 14986051].
Burch JA, Soares-Weiser K, St John DJ, et al. Diagnostic accuracy of faecal occult blood tests used in screening for colorectal cancer: a systematic review. J Med Screen. 2007;14:132-137. Excluded for study design. [pmid: 17925085].
Burling D, Halligan S, Taylor S, et al. Polyp measurement using CT colonography: agreement with colonoscopy and effect of viewing conditions on interobserver and intraobserver agreement. AJR American Journal of Roentgenology. 2006;186(6):1597-604. Did not report necessary outcomes. [pmid: 16714648].
Burling D, Halligan S, Taylor SA, Honeyfield L, Roddie ME. CT colonography: automatic measurement of polyp diameter compared with manual assessment - an in-vivo study. Clinical Radiology. 2007;62(2):145-51. Did not report necessary outcomes. [pmid: 17207697].
Calistri D, et al. Fecal Multiple Molecular Test to Detect Colorectal Cancer Screening in Stool. Clinical Gastroenterology and Hepatology. 2003;1:377-383. Excluded for population with cancer. [pmid: 15017656].
Cash BD, Kim C, Cullen P, et al. Accuracy of computed tomographic colonography for colorectal cancer (CRC) screening in asymptomatic individuals. Gastroenterology. 2006;130:A46. Excluded for study design.
Cash BD, Schoenfeld P, Rex D. An evidence-based medicine approach to studies of diagnostic tests: assessing the validity of virtual colonoscopy. Clin Gastroenterol Hepatol. 2003;1:136-144. Inadequate application of reference standard. [pmid: 15017506].
Castiglione G, Grazzini G, Miccinesi G, et al. Basic variables at different positivity thresholds of a quantitative immunochemical test for faecal occult blood. J Med Screen. 2002;9:99-103. Did not report necessary outcomes. [pmid: 12370319].
Castiglione G, Sala P, Ciatto S, et al. Comparative analysis of results of guaiac and immunochemical tests for faecal occult blood in colorectal cancer screening in two oncological institutions. European Journal of Cancer Prevention. 1994;3(5):399-405. Excluded for population. [pmid: 8000308].
Castiglione G, Visioli CB, Ciatto S, Grazzini G, Bonanomi AG, Rubeca T, Mantellini P, Zappa M. Sensitivity of latex agglutination faecal occult blood test in the Florence District population-based colorectal cancer screening programme. British Journal of Cancer. 2007;96(11):1750-4. Excluded for study design. [pmid: 17453007].
Castiglione G, Zappa M, Grazzini G, et al. Immunochemical vs guaiac faecal occult blood tests in a population-based screening programme for colorectal cancer. British Journal of Cancer. 1996;74(1):141-4. Inadequate application of reference standard. [pmid: 8679448].
Castiglione G, Zappa M, Grazzini G, et al. Screening for colorectal cancer by faecal occult blood test: comparison of immunochemical tests. Journal of Medical Screening. 2000;7(1):35-7. Excluded for quality Validation on subset 2×2. [pmid: 10807145].
Chen HS, Sheen-Chen SM. Influence of age and gender on surveillance for colorectal tumors in low-risk asymptomatic population. Anticancer Res. 2002;22:399-403. Did not report necessary outcomes. [pmid: 12017322].
Chen JC, Dachman AH. Cecal mobility: a potential pitfall of CT colonography. Am J Roentgenol. 2006;186:1086-1089. Did not report necessary outcomes. [pmid: 16554583].
Chen K, Jiao DA, Zheng S, Zhou S, Yu H. Diagnostic value of fecal occult blood testing for screening colorectal cancer. China National Journal New Gastroenterology. 1997;3(3):166-168. Excluded for population: Outcomes.
Cohnen M, Vogt C, Aurich V, Beck A, Haussinger D, Modder U. Multi-slice CT-colonography in low-dose technique—Preliminary results. Rofo: Fortschritte auf dem Gebiete der Rontgenstrahlen und der Nuklearmedizin. 2002;174:835-838. Excluded for population. [pmid: 12101472].
Cohnen M, Vogt C, Beck A et al. Feasibility of MDCT Colonography in ultra-low-dose technique in the detection of colorectal lesions: comparison with high-resolution video colonoscopy. AJR. 2004;American:1355–1359. Excluded for population
Cotton PB, Durkalski VL, Pineau BC, et al. Computed tomographic colonography (virtual colonoscopy): a multicenter comparison with standard colonoscopy for detection of colorectal neoplasia. JAMA. 2004;291:1713-1719. Excluded for population. [pmid: 15082698].
Crawford NP, Colliver DW, Galandiuk S. Tumor markers and colorectal cancer: utility in management. J Surg Oncol. 2003;84:239-248. Excluded for study design. [pmid: 14756436].
Cruz-Correa M, Schultz K, Jagannath S, et al. Performance characteristics and comparison of two fecal occult blood tests in patients undergoing colonoscopy. Dig Dis Sci. 2007;52:1009-1013. Did not include one of the specific screening tests. [pmid: 17380401].
Dachman AH, Lefere P, Gryspeerdt S, Morin M. CT colonography: visualization methods, interpretation, and pitfalls. Radiologic Clinics of North America. 2007;45(2):347-59. Excluded for study design. [pmid: 17502222].
Deenadayalu DP, Rex DK. Fecal-based DNA assays: A new, noninvasive approach to colorectal cancer screening. Cleveland Clinic Journal of Medicine. 2004;71:497-503. Excluded for population with cancer. [pmid: 15242305].
Dehmeshki J, Halligan S, Taylor SA, et al. Computer assisted detection software for CT colonography: effect of sphericity filter on performance characteristics for patients with and without fecal tagging. European Radiology. 2007;17(3):662-8. Did not answer primary question. [pmid: 17021701].
Dong SM, et al. Detecting Colorectal Cancer in Stool With the Use of Multiple Genetic Targets. Journal of the National Cancer Institute. 2001;93(11):858-865. Excluded for population with cancer. [pmid: 11390535].
Duff SE, Murray D, Rate AJ, Richards DM, Kumar NA. Computed tomographic colonography (CTC) performance: one-year clinical follow-up. Clinical Radiology. 2006;61(11):932-6. Excluded for population. [pmid: 17018305].
ECRI. Fecal DNA testing for colorectal cancer (CRC). 2006. ECRI. Source document
Edwards JT, Mendelson RM, Fritschi L, et al. Colorectal neoplasia screening with CT colonography in average-risk asymptomatic subjects: community-based study. Radiology. 2004;230(2):459-64. Inadequate application of reference standard. [pmid: 14688402].
Eguchi S, et al. Mutations fo the p53 Gene in the Stool of Patient with Resectable colorectal Cancer. Cancer. 1996;77(Suppl):1707-1710. Excluded for population with cancer. [pmid: 8608566].
Erturk SM, Mortele KJ, Oliva MR, Barish MA. State-of-the-art computed tomographic and magnetic resonance imaging of the gastrointestinal system. Gastrointestinal Endoscopy Clinics of North America. 2005;15(3):581-614. Excluded for study design. [pmid: 15990058].
Fattah AS, Nakama H, Kamijo N, Fujimori K, Zhang B. Colorectal adenomatous polyps detected by immunochemical occult blood screening. Hepato-Gastroenterology. 1998;45(21):712-6. Excluded for study design. [pmid: 9684121].
Ferrucci JT. Colon cancer screening with virtual colonoscopy: promise, polyps, politics. AJR. 2001;177:975-988. Excluded for study design. [pmid: 11641151].
Fletcher JG, Booya F, Melton Z, et al. Automated polyp measurement with CT colonography: preliminary observations in a phantom colon model. Am J Roentgenol. 2007;188:945-952. Did not answer primary question. [pmid: 17377028].
Florie J, van Gelder RE, Stoker J. Colonography by computed tomography. European Journal of Gastroenterology & Hepatology. 2005;17:809-813. Excluded for study design. [pmid: 16003128].
Fraser CG, Matthew CM, Mowat NA, Wilson JA, Carey FA, Steele RJ. Immunochemical testing of individuals positive for guaiac faecal occult blood test in a screening programme for colorectal cancer: an observational study. Lancet Oncology. 2006;7(2):127-31. Excluded for population. [pmid: 16455476].
Fraser CG, Matthew CM, Mowat NA, Wilson JA, Carey FA, Steele RJ. Evaluation of a card collection based faecal immunochemical test in screening for colorectal cancer using a two-tier reflex approach. Gut. 2007;56(10):1415-8. Excluded for population. [pmid: 17309886].
Ganeshan A, Upponi S, Uberoi R, D'Costa H, Picking C, Bungay H. Minimal-preparation CT colon in detection of colonic cancer, the Oxford experience. Age & Ageing. 2007;36(1):48-52. Excluded for study design. [pmid: 17114203].
Gluecker T, Dorta G, Keller W, Jornod P, Meuli R, Schnyder P. Performance of multidetector computed tomography colonography compared with conventional colonoscopy. Gut. 2002;51:207-211. Excluded for population. [pmid: 12117881].
Gluecker T, Meuwly JY, Pescatore P, et al. Effect of investigator experience in CT colonography. Eur Radiol. 2002;12:1405-1409. Excluded for population. [pmid: 12042946].
Gopalswamy N, Stelling HP, Markert RJ, Maimon HN, Wahlen SD, Haddy RI. A comparative study of eight fecal occult blood tests and HemoQuant in patients in whom colonoscopy is indicated. Arch Fam Med. 1994;3:1043-1048. Excluded for population. [pmid: 7804488].
Grazzini G, Castiglione G, Isu A, et al. Colorectal cancer screening by fecal occult blood testing: results of a population-based experience. Tumori. 2000;86(5):384-8. Inadequate application of reference standard. [pmid: 11130566].
Greenberg PD, Bertario L, Gnauck R, et al. A prospective multicenter evaluation of new fecal occult blood tests in patients undergoing colonoscopy. Am J Gastroenterol. 2000;95:1331-1338. Excluded for population-high proportion screen positive or symptomatic. [pmid: 10811348].
Guittet L, Bouvier V, Mariotte N, et al. Comparison of a guaiac based and an immunochemical faecal occult blood test in screening for colorectal cancer in a general average risk population. Gut. 2007;56(2):210-4. Inadequate application of reference standard. [pmid: 16891354].
Halligan Duplicative review content. Does not provide additional primary articles
Halligan S, Altman DG, Mallett S, et al. Computed tomographic colonography: assessment of radiologist performance with and without computer-aided detection. Gastroenterology. 2006;131(6):1690-9. Excluded for population. [pmid: 17087934].
Halligan S, Altman DG, Taylor SA, et al. CT colonography in the detection of colorectal polyps and cancer: systematic review, meta-analysis, and proposed minimum data set for study level reporting. Radiology. 2005;237:893-904. Excluded for study design. [pmid: 16304111].
Halligan S, Park SH, Ha HK. Causes of false-negative findings at CT colonography. Radiology. 2006;238:1075-1076. Excluded for study design. [pmid: 16505404].
Halligan S, Taylor SA, Dehmeshki J, et al. Computer-assisted detection for CT colonography: external validation. Clinical Radiology. 2006;61(9):758-63. discussion 764–5. Did not answer primary question. [pmid: 16905382].
Halligan S, Taylor SA. CT colonography: Results and limitations. European Journal of Radiology. 2007;61(3):400-8. Excluded for study design. [pmid: 17174055].
Hara AK, Johnson CD, Reed JE, et al. Detection of colorectal polyps with CT colography: initial assessment of sensitivity and specificity. Radiology. 1997;205:59-65. Excluded for population. [pmid: 9314963].
Harewood GC. What is the most sensitive screening method for the detection of colon cancer? Nature Clinical Practice Gastroenterology & Hepatology 2005;134–5. Excluded for study design
Hasegawa Y, et al. Detection of K-ras mutation in DNAs isolated from feces of patients with colorectal tumors by mutant-allele-specific amplicication (MASA). Oncogene. 1995;10:1441-1445. Excluded for population with cancer. [pmid: 7731696].
Haug U, Brenner H. New stool tests for colorectal cancer screening: a systematic review focusing on performance characteristics and practicalness. Int J Cancer. 2005;117:169-176. Source document. [pmid: 15880368].
Haug U, Wente MN, Seiler CM, Rothenbacher D, Buchler MW, Brenner H. Tumor M2 pyruvate kinase as a stool marker for colorectal cancer: stability at room temperature and implications for application in the screening setting. Clinical Chemistry. 2006;52(4):782-4. Excluded for study relevance. [pmid: 16595841].
HAYES and Inc. Computed Tomography Colonography (Virtual Colonoscopy). 2006. Lansdale, PA: HAYES, Inc. Source document
HAYES and Inc. Fecal DNA testing for colorectal cancer screening and monitoring. 2002. Lansdale, PA: HAYES, Inc. Source document
Haykir R, Karakose S, Karabacakoglu A, Sahin M, Kayacetin E. Three-dimensional MR and axial CT colonography versus conventional colonoscopy for detection of colon pathologies. World Journal of Gastroenterology. 2006;12:2345-2350. Excluded for population. [pmid: 16688823].
Hoepffner N, Shastri YM, Hanisch E, et al. Comparative evaluation of a new bedside faecal occult blood test in a prospective multicentre study. Alimentary Pharmacology & Therapeutics. 2006;23(1):145-54. Excluded for population. [pmid: 16393292].
Hoff G, Grotmol T, Thiis-Evensen E, Bretthauer M, Gondal G, Vatn MH. Testing for faecal calprotectin (PhiCal) in the Norwegian Colorectal Cancer Prevention trial on flexible sigmoidoscopy screening: comparison with an immunochemical test for occult blood (FlexSure OBT). Gut. 2004;53:1329-1333. Excluded for study relevance. [pmid: 15306594].
Hope RL, Chu G, Hope AH, Newcombe RG, Gillespie PE, Williams SJ. Comparison of three faecal occult blood tests in the detection of colorectal neoplasia. Gut. 1996;39(5):722-5. Excluded for population. [pmid: 9014773].
Hoppe H, Quattropani C, Spreng A, Mattich J, Netzer P, Dinkel HP. Virtual colon dissection with CT colonography compared with axial interpretation and conventional colonoscopy: preliminary results. AJR. 2004;American:1151–1158. Excluded for population
Hughes K, Leggett B, Del Mar C, et al. Guaiac versus immunochemical tests: faecal occult blood test screening for colorectal cancer in a rural community. Australian & New Zealand Journal of Public Health. 2005;29(4):358-64. Did not report necessary outcomes. [pmid: 16222934].
Hwang I, Wong RK. Limitations of virtual colonoscopy. Ann Intern Med. 2005;142(2):154-155. Excluded for study design. [pmid: 15657168].
Iannaccone R, Catalano C, Mangiapane F, et al. Colorectal polyps: detection with low-dose multi-detector row helical CT colonography versus two sequential colonoscopies. Radiology. 2005;237:927-937. Excluded for population. [pmid: 16304113].
Iannaccone R, Laghi A, Catalano C, et al. Computed tomographic colonography without cathartic preparation for the detection of colorectal polyps. Gastroenterology. 2004;127:1300-1311. Excluded for population. [pmid: 15520999].
Iannaccone R, Laghi A, Catalano C, et al. Detection of colorectal lesions: lower-dose multi-detector row helical CT colonography compared with conventional colonoscopy. Radiology. 2003;229:775-781. Excluded for population. [pmid: 14657315].
Itzkowitz SH, Jandorf L, Brand R, et al. Improved fecal DNA test for colorectal cancer screening. Clinical Gastroenterology & Hepatology. 2007;5(1):111-7. Excluded due to study design. [pmid: 17161655].
Jeanson A, Jamart J, Maisin JM, et al. Assessment of the new immunological test Hemoblot for detecting occult blood in faeces. Eur J Cancer Prev. 1994;3:407-412. Excluded for population. [pmid: 8000309].
Jensch S, van Gelder RE, Florie J, et al. Performance of radiographers in the evaluation of CT colonographic images. AJR American Journal of Roentgenology. 2007;188(3):W249-55. Excluded for population. [pmid: 17312031].
Johnson CD, MacCarty RL, Welch TJ, et al. Comparison of the relative sensitivity of CT colonography and double-contrast barium enema for screen detection of colorectal polyps. Clinical Gastroenterology & Hepatology. 2004;2(4):314-21. Inadequate application of reference standard. [pmid: 15067626].
Johnson CD, Toledano AY, Herman BA, et al. The clinical role of extracellular bioimpedance tomography (Gastro-Mida(x)) in the diagnosis of colorectal diseases. Gastroenterology. 2003;125(3):688-95. Excluded for population. [pmid: 12949715].
Juchems MS, Fleiter TR, Pauls S, Schmidt SA, Brambs HJ, Aschoff AJ. CT colonography: comparison of a colon dissection display versus 3D endoluminal view for the detection of polyps. European Radiology. 2006;16(1):68-72. Excluded for population. [pmid: 16402257].
Kalra N, Suri S, Bhasin DK, et al. Comparison of multidetector computed tomographic colonography and conventional colonoscopy for detection of colorectal polyps and cancer. Indian Journal of Gastroenterology. 2006;25(5):229-32. Excluded for population. [pmid: 17090838].
Kay CL, Kulling D, Hawes RH, Young JW, Cotton PB. Virtual endoscopy—comparison with colonoscopy in the detection of space-occupying lesions of the colon. Endoscopy. 2000;32(3):226-32. Excluded for population. [pmid: 10718388].
Lefkovitz Z, Shapiro R, Koch S, Cappell MS. The emerging role of virtual colonoscopy. Med Clin North Am. 2005;89:111–38, viii. Excluded for study design
Lenhard K, Bommer GT, Asutay S, et al. Analysis of promoter methylation in stool: a novel method for the detection of colorectal cancer. Clinical Gastroenterology & Hepatology. 2005;3:142-149. Excluded for population. [pmid: 15704048].
Levi Z, Hazazi R, Rozen P, Vilkin A, Waked A, Niv Y. A quantitative immunochemical faecal occult blood test is more efficient for detecting significant colorectal neoplasia than a sensitive guaiac test. Alimentary Pharmacology & Therapeutics. 2006;23:1359-1364. Excluded for population. [pmid: 16629942].
Levi Z, Rozen P, Hazazi R, et al. Can quantification of faecal occult blood predetermine the need for colonoscopy in patients at risk for non-syndromic familial colorectal cancer?. Alimentary Pharmacology & Therapeutics. 2006;24:1475-1481. Excluded for population-proportion of symptomatic patients <10%. [pmid: 17032281].
Levin B, Hess K, Johnson C. Screening for colorectal cancer. A comparison of 3 fecal occult blood tests. Archives of Internal Medicine. 1997;157(9):970-6. Excluded for quality: low followup rates. [pmid: 9140267].
Li S, Wang H, Hu J, et al. New immunochemical fecal occult blood test with two-consecutive stool sample testing is a cost-effective approach for colon cancer screening: results of a prospective multicenter study in Chinese patients. International Journal of Cancer. 2006;118(12):3078-83. Excluded for population.
Lida Y, Munemoto Y, Miura S, et al. Clinicopathologic studies of immunologic fecal occult blood test for colorectal cancer. J Gastroenterol. 1995;30:192-200. Excluded for population. [pmid: 7773350].
Lin OS, Kozarek RA, Schembre DB, et al. Risk stratification for colon neoplasia: screening strategies using colonoscopy and computerized tomographic colonography. Gastroenterology. 2006;131:1011-1019. Excluded for study design. [pmid: 17030171].
Liu HH, Huang TW, Chen HL, Wang TH, Lin JT. Clinicopathologic significance of immunohistochemical fecal occult blood test in subjects receiving bidirectional endoscopy. Hepatogastroenterology. 2003;50:1390-1392. Did not report correct outcomes. [pmid: 14571744].
Macari M, Bini EJ, Xue X, et al. Colorectal neoplasms: prospective comparison of thin-section low-dose multi-detector row CT colonography and conventional colonoscopy for detection. Radiology. 2002;224:383-392. Excluded for population. [pmid: 12147833].
Macari M, Bini EJ. CT colonography: where have we been and where are we going?. Radiology. 2005;237(3):819-33. Excluded for study design. [pmid: 16237143].
MacCarty RL, Johnson CD, Fletcher JG, Wilson LA. Occult colorectal polyps on CT colonography: implications for surveillance. AJR American Journal of Roentgenology. 2006;186(5):1380-3. Excluded for population. [pmid: 16632734].
Mak T, Lalloo F, Evans DG, Hill J. Molecular stool screening for colorectal cancer. Br J Surg. 2004;91:790-800. Excluded for study design. [pmid: 15227685].
McFarland EG, Pilgram TK, Brink JA, et al. CT colonography: multiobserver diagnostic performance. Radiology. 2002;225:380-390. Excluded for population. [pmid: 12409570].
Medical Services Advisory Committee. Faecal occult blood testing for population health screening. 2004. Canberra: Medical Services Advisory Committee (MSAC). Duplicative review content. Does not provide additional primary articles
Menardo G. Sensitivity of diagnostic examinations for colorectal polyps. Techniques in Coloproctology 8 Suppl 2004;2:s273 –5. Excluded for study design
Miyoshi H, Oka M, Sugi K, Saitoh O, Katsu K, Uchida K. Accuracy of detection of colorectal neoplasia using an immunochemical occult blood test in symptomatic referred patients: comparison of retrospective and prospective studies. Intern Med. 2000;39:701-706. Excluded for population. [pmid: 10969900].
Munikrishnan V, Gillams AR, Lees WR, Vaizey CJ, Boulos PB. Prospective study comparing multislice CT colonography with colonoscopy in the detection of colorectal cancer and polyps. Diseases of the Colon & Rectum. 2003;46:1384-1390. Excluded for population. [pmid: 14530680].
Nakajima M, Saito H, Soma Y, Sobue T, Tanaka M, Munakata A. Prevention of advanced colorectal cancer by screening using the immunochemical faecal occult blood test: a case-control study. British Journal of Cancer. 2003;89(1):23-8. Excluded for study design. [pmid: 12838295].
Nakama H, bdul Fattah AS, Zhang B, Kamijo N, Fujimori K, Miyata K. Detection rate of immunochemical fecal occult blood test for colorectal adenomatous polyps with severe dysplasia. Journal of Gastroenterology. 1997;32(4):492-5. Excluded for study design. [pmid: 9250896].
Nakama H, Fattah A, Zhang B, Uehara Y, Wang C. A comparative study of immunochemical fecal tests for detection of colorectal adenomatous polyps. Hepatogastroenterology. 2000;47:386-389. Excluded for study design. [pmid: 10791196].
Nakama H, Kamijo N, Fattah AS, Zhang B. Immunologic detection of fecal occult blood from upper digestive tract diseases. Hepato-Gastroenterology. 1998;45(21):752-4. Excluded for population. [pmid: 9684127].
Nakama H, Kamijo N, Fujimori K, Fattah AS, Zhang B. Relationship between fecal sampling times and sensitivity and specificity of immunochemical fecal occult blood tests for colorectal cancer: a comparative study. Diseases of the Colon & Rectum. 1997;40(7):781-4. Excluded for study design. [pmid: 9221852].
Nakama H, Kamijo N, Fujimori K, Horiuchi A, Fattah AS, Zhang B. Characteristics of colorectal cancer with false negative result on immunochemical faecal occult blood test. J Med Screen. 1996;3:115-118. Excluded for study design. [pmid: 8946304].
Nakama H, Kamijo N, Miyata K, bdul Fattah AS, Zhang B, Uehara Y. Sensitivity and specificity of several immunochemical tests for colorectal cancer. Hepato-Gastroenterology. 1998;45(23):1579-82. Excluded for study design. [pmid: 9840108].
Nakama H, Kamijo N. Accuracy of immunological fecal occult blood testing for colorectal cancer screening. Prev Med. 1994;23:309-313. Excluded for study design. [pmid: 8078851].
Nakama H, Kayano T, Katsuura T, et al. Comparison of predictive value for colorectal cancer in subjects with and without rectal bleeding. Hepato-Gastroenterology. 1999;46(27):1730-2. Excluded for study design. [pmid: 10430332].
Nakama H, Zhang B, bdul Fattah AS, Kamijo N, Fukazawa K. Relationships between a sign of rectal bleeding and the results of an immunochemical occult blood test, and colorectal cancer. European Journal of Cancer Prevention. 2000;9(5):325-8. Did not report necessary outcomes. [pmid: 11075885].
Nakama H, Zhang B, Fattah AA, Kamijo N, Zhang X. Characteristics of colorectal cancer that produce positive immunochemical occult blood test results on stool obtained by digital rectal examination. Can J Gastroenterol. 2001;15:227-230. Excluded for quality. [pmid: 11331923].
Nakama H, Zhang B, Fattah AS, Zhang X. Colorectal cancer in iron deficiency anemia with a positive result on immunochemical fecal occult blood. Int J Colorectal Dis. 2000;15:271-274. Did not report necessary outcomes. [pmid: 11151429].
Nakama H, Zhang B, Kamijo N. Sensitivity of immunochemical fecal occult blood test for colorectal flat adenomas. Hepato-Gastroenterology. 2004;51(59):1333-6. Excluded for study design. [pmid: 15362746].
Ness R, et al. The Cost-Effectiveness of Fecal DNA Testing for Colorectal Cancer. Gastroenterology. 2003;124(4):Suppl A458. Abstract only.
Nio CY, de Vries AH, Stoker J. Perceptive errors in CT colonography. Abdom Imaging. 2006. (Epub ahead of print) Excluded for study design
Nollau P, et al. Detection of K-ras Mutations in Stools of Patients with Colorectal Cancer by Mutant-Enriched PCR. International Journal of Cancer. 1996;66:332-336. Excluded for population with cancer.
Novis B. A comparison of virtual and conventional colonoscopy for the detection of colorectal polyps. Gastrointest Endosc. 2000;52:700-701. Excluded for study design. [pmid: 11203438].
O'Connor SD, Summers RM, Yao J, Pickhardt PJ, Choi JR. CT colonography with computer-aided polyp detection: volume and attenuation thresholds to reduce false-positive findings owing to the ileocecal valve. Radiology. 2006;241(2):426-32. Did not report necessary outcomes. [pmid: 17005773].
O'Hare A, Fenlon H. Virtual colonoscopy in the detection of colonic polyps and neoplasms. Best Practice & Research in Clinical Gastroenterology. 2006;79–92. Excluded for study design
Ontario Ministry of Health and Long-Term Care. Computed tomographic colonography (virtual colonoscopy). 2003. Toronto: Medical Advisory Secretariat, Ontario Ministry of Health and Long-Term Care (MAS). Excluded for study design
Park SH, Ha HK, Kim MJ, et al. False-negative results at multi-detector row CT colonography: multivariate analysis of causes for missed lesions. Radiology. 2005;235:495-502. Excluded for population. [pmid: 15770042].
Pescatore P, Glucker T, Delarive J, et al. Diagnostic accuracy and interobserver agreement of CT colonography (virtual colonoscopy). Gut. 2000;47(1):126-30. Excluded for population. [pmid: 10861274].
Petrelli N, Michalek AM, Freedman A, Baroni M, Mink I, Rodriguez-Bigas M. Immunochemical versus guaiac occult blood stool tests: results of a community-based screening program. Surgical Oncology. 1994;3(1):27-36. Excluded for quality: low followup. [pmid: 8186868].
Pickhardt PJ, Lehman VT, Winter TC, Taylor AJ. Polyp volume versus linear size measurements at CT colonography: implications for noninvasive surveillance of unresected colorectal lesions. AJR American Journal of Roentgenology. 2006;186(6):1605-10. Did not report correct outcomes. [pmid: 16714649].
Pickhardt PJ, Nugent PA, Mysliwiec PA, Choi JR, Schindler WR. Location of adenomas missed by optical colonoscopy. Annals of Internal Medicine. 2004;141(5):352-9. Did not report necessary outcomes. [pmid: 15353426].
Pineau BC, Paskett ED, Chen GJ, et al. Virtual colonoscopy using oral contrast compared with colonoscopy for the detection of patients with colorectal polyps. Gastroenterology. 2003;125(2):304-10. Excluded for population. [pmid: 12891529].
Pineau BC, Paskett ED, Chen GJ, Durkalski VL, Espeland MA, Vining DJ. Validation of virtual colonoscopy in the detection of colorectal polyps and masses: rationale for proper study design. International Journal of Gastrointestinal Cancer. 2001;30(3):133-40. Did not report necessary outcomes. [pmid: 12540025].
Rennert G, Rennert HS, Miron E, Peterburg Y. Population colorectal cancer screening with fecal occult blood test. Cancer Epidemiology, Biomarkers & Prevention. 2001;10:1165-1168. Excluded for study design.
Rennert G. Fecal occult blood screening—trial evidence, practice and beyond. Recent Results Cancer Res. 2003;163:248-253. Inadequate application of reference standard. [pmid: 12903859].
Reuterskiold MH, Lasson A, Svensson E, Kilander A, Stotzer PO, Hellstrom M. Diagnostic performance of computed tomography colonography in symptomatic patients and in patients with increased risk for colorectal disease. Acta Radiologica. 2006;47(9):888-98. Excluded for population. [pmid: 17077037].
Robinson MH, Marks CG, Farrands PA, Thomas WM, Hardcastle JD. Population screening for colorectal cancer: comparison between guaiac and immunological faecal occult blood tests. British Journal of Surgery. 1994;81(3):448-51. Inadequate application of reference standard. [pmid: 8173928].
Robinson MH, Marks CG, Farrands PA, Whynes DK, Bostock K, Hardcastle JD. Is an immunological faecal occult blood test better than Haemoccult? A cost-benefit study. European Journal of Surgical Oncology. 1995;21(3):261-4. Inadequate application of reference standard. [pmid: 7781793].
Rosman AS, Korsten MA. Meta-analysis comparing CT colonography, air contrast barium enema, and colonoscopy. Am J Med. 2007;120:203-210. Excluded for population. [pmid: 17349438].
Rozen P, Knaani J, Papo N. Evaluation and comparison of an immunochemical and a guaiac faecal occult blood screening test for colorectal neoplasia. European Journal of Cancer Prevention. 1995;4(6):475-81. Excluded for population: high proportion of surveillance and sypmtomatic. [pmid: 8580783].
Rozen P, Knaani J, Samuel Z. Comparative screening with a sensitive guaiac and specific immunochemical occult blood test in an endoscopic study. Cancer. 2000;89(1):46-52. Inadequate application of reference standard. [pmid: 10896999].
Rozen P, Knaani J, Samuel Z. Performance characteristics and comparison of two immunochemical and two guaiac fecal occult blood screening tests for colorectal neoplasia. Digestive Diseases & Sciences. 1997;42(10):2064-71. Inadequate application of reference standard. [pmid: 9365136].
Saar B, Meining A, Beer A, et al. Prospective study on bright lumen magnetic resonance colonography in comparison with conventional colonoscopy. British Journal of Radiology. 2007;80(952):235-41. Excluded for population. [pmid: 17329681].
Saito H, Soma Y, Nakajima M, et al. A case-control study evaluating occult blood screening for colorectal cancer with hemoccult test and an immunochemical hemagglutination test. Oncol Rep. 2000;7:815-819. Excluded for study design. [pmid: 10854550].
Saito H. Screening for colorectal cancer: current status in Japan. Diseases of the Colon & Rectum. 2000;43(Suppl):84. Excluded for study design.
Saitoh O, Kojima K, Kayazawa M, et al. Comparison of tests for fecal lactoferrin and fecal occult blood for colorectal diseases: a prospective pilot study. Intern Med. 2000;39:778-782. Excluded for population-high proportion screen positive or symptomatic. [pmid: 11030199].
Scholefield JH. Immunochemical testing for colorectal cancer. Lancet Oncology. 2006;7(2):101-3. Excluded for study design. [pmid: 16455472].
Scott RG, Edwards JT, Fritschi L, Foster NM, Mendelson RM, Forbes GM. Community-based screening by colonoscopy or computed tomographic colonography in asymptomatic average-risk subjects. The American journal of gastroenterology. 2004;99:1145-1151. Inadequate application of reference standard. [pmid: 15180739].
Selcuk D, Demirel K, Ozer H, et al. Comparison of virtual colonoscopy with conventional colonoscopy in detection of colorectal polyps. Turkish Journal of Gastroenterology. 2006;17(4):288-93. Excluded for population. [pmid: 17205408].
Shastri YM, Naumann M, Oremek GM, et al. Prospective multicenter evaluation of fecal tumor pyruvate kinase type M2 (M2-PK) as a screening biomarker for colorectal neoplasia. International Journal of Cancer. 2006;119(11):2651-6. Did not include one of the specific screening tests.
Shi R, Schraedley-Desmond P, Napel S, et al. CT colonography: influence of 3D viewing and polyp candidate features on interpretation with computer-aided detection. Radiology. 2006;239(3):768-76. Excluded for population. [pmid: 16714460].
Shuber AP, et al. A Discriminant DNA Marker Panel for Detection of Colorectal Adenomas. American Journal of Gastroenterology. 2005;100(9):393. Abstract only.
Sidransky D, et al. Identification of ras Oncogene Mutations in the stool of patients with Curable Colorectal Tumors. Science. 1992;256:102-105. Excluded for population with cancer. [pmid: 1566048].
Smith A, Young GP, Cole SR, Bampton P. Comparison of a brush-sampling fecal immunochemical test for hemoglobin with a sensitive guaiac-based fecal occult blood test in detection of colorectal neoplasia. Cancer. 2006;107:2152-2159. Excluded for population-high proportion of screen positive. [pmid: 16998938].
Smith-Ravin J, et al. Detection of c-Ki-ras mutations in faecal samples from sporadic colorectal cancer patients. Gut. 1995;36:81-86. Excluded for population with cancer. [pmid: 7890240].
Sosna J, Morrin MM, Kruskal JB, Lavin PT, Rosen MP, Raptopoulos V. CT colonography of colorectal polyps: a metaanalysis. AJR Am J Roentgenol. 2003;181:1593-1598. Used as source document. [pmid: 14627580].
Spinzi G, Belloni G, Martegani A, Sangiovanni A, Del FC, Minoli G. Computed tomographic colonography and conventional colonoscopy for colon diseases: a prospective, blinded study. Am J Gastroenterol. 2001;96:394-400. Excluded for population. [pmid: 11232681].
St John DJ, Young GP, McHutchison JG, Deacon MC, Alexeyeff MA. Comparison of the specificity and sensitivity of Hemoccult and HemoQuant in screening for colorectal neoplasia. Annals of Internal Medicine. 1992;117(5):376-82. Excluded for population. [pmid: 1503328].
Stelling HP, Maimon HN, Smith RA, Haddy RI, Markert RJ. A comparative study of fecal occult blood tests for early detection of gastrointestinal pathology. Arch Intern Med. 1990;150:1001-1005. Excluded for population. [pmid: 2331181].
Summers RM, Yao J, Pickhardt PJ, et al. Computed tomographic virtual colonoscopy computer-aided polyp detection in a screening population. Gastroenterology. 2005;129(6):1832-44. Did not answer primary question. [pmid: 16344052].
Syngal S, Stoffel E, Chung D, et al. Detection of stool DNA mutations before and after treatment of colorectal neoplasia. Cancer. 2006;106(2):277-83. Excluded for population. [pmid: 16342248].
Tagore KS, Lawson MJ, Yucaitis JA, et al. Sensitivity and specificity of a stool DNA multitarget assay panel for the detection of advanced colorectal neoplasia. Clinical Colorectal Cancer. 2003;3(1):47-53. Excluded for population. [pmid: 12777192].
Thomeer M, Carbone I, Bosmans H, et al. Stool tagging applied in thin-slice multidetector computed tomography colonography. J Comput Assist Tomogr. 2003;27:132-139. Excluded for population. [pmid: 12703001].
Tonus C, Neupert G, Sellinger M. Colorectal cancer screening by non-invasive metabolic biomarker fecal tumor M2-PK. World Journal of Gastroenterology. 2006;12(43):7007-11. Did not include one of the specific screening tests. [pmid: 17109496].
Traverso G, et al. Detection of APC Mutation in Fecal DNA from Patients with Colorectal Tumors. The New England Journal of Medicine. 2002;346:311-320. Excluded for population with cancer. [pmid: 11821507].
Traverso G, Shuber A, Olsson L, et al. Detection of proximal colorectal cancers through analysis of faecal DNA. Lancet. 2002;359:403-404. Excluded for population. [pmid: 11844514].
Uchida K, Matsuse R, Miyachi N, et al. Immunochemical detection of human blood in feces. Clinica Chimica Acta. 1990;189(3):267-74. Excluded for study design.
van Gelder RE, Florie J, Stoker J. Colorectal cancer screening and surveillance with CT colonography: current controversies and obstacles. Abdominal Imaging. 2005;30(1):5-12. Excluded for study design. [pmid: 15647865].
Vilkin A, Rozen P, Levi Z, et al. Performance characteristics and evaluation of an automated-developed and quantitative, immunochemical, fecal occult blood screening test. American Journal of Gastroenterology. 2005;100(11):2519-25. Excluded for population. [pmid: 16279909].
Villa E, et al. Identification of Subjects at Risk for Colorectal Carcinoma Through a Test Based on K-ras Determiniation in the stool. Gastroenterology. 1996;110:1346-1353. Excluded for population with cancer. [pmid: 8613038].
Vironen J, Kellokumpu S, Andersson LC, Kellokumpu I. Comparison of a peanut agglutinin test and an immunochemical faecal occult blood test in detecting colorectal neoplasia in symptomatic patients. Scandinavian Journal of Clinical & Laboratory Investigation. 2004;64(2):140-5. Excluded for population. [pmid: 15115252].
Wessling J, Domagk D, Lugering N, et al. Virtual colonography: identification and differentiation of colorectal lesions using multi-detector computed tomography. Scandinavian Journal of Gastroenterology. 2005;40(4):468-76. Excluded to to study quality. [pmid: 16028443].
Whitney D, Skoletsky J, Moore K, et al. Enhanced retrieval of DNA from human fecal samples results in improved performance of colorectal cancer screening test. Journal of Molecular Diagnostics. 2004;6(4):386-95. Excluded for population. [pmid: 15507679].
Wong BC, Wong WM, Cheung KL, et al. A sensitive guaiac faecal occult blood test is less useful than an immunochemical test for colorectal cancer screening in a Chinese population. Alimentary Pharmacology & Therapeutics. 2003;18:941-946. Excluded for population. [pmid: 14616158].
Wong WM, Lam SK, Cheung KL, et al. Evaluation of an automated immunochemical fecal occult blood test for colorectal neoplasia detection in a Chinese population. Cancer. 2003;97(10):2420-4. Excluded for population. [pmid: 12733140].
Woo HY, Mok RS, Park YN, et al. A prospective study of a new immunochemical fecal occult blood test in Korean patients referred for colonoscopy. Clin Biochem. 2005;38:395-399. Excluded for population. [pmid: 15766742].
Xing PX, Young GP, Ho D, Sinatra MA, Hoj PB, McKenzie IF. A new approach to fecal occult blood testing based on the detection of haptoglobin. Cancer. 1996;78:48-56. Excluded for population. [pmid: 8646726].
Xynopoulos D, Stasinopoulou M, Dimitroulopoulos D, et al. Colorectal polyp detection with virtual colonoscopy (computed tomographic colonography); the reliability of the method. Hepato-Gastroenterology. 2002;49(43):124-7. Excluded for population. [pmid: 11941935].
Yamamoto M, Nakama H. Cost-effectiveness analysis of immunochemical occult blood screening for colorectal cancer among three fecal sampling methods. Hepato-Gastroenterology. 2000;47(32):396-9. Apr. Inadequate application of reference standard. [pmid: 10791199].
Yasumoto T, Murakami T, Yamamoto H, et al. Assessment of two 3D MDCT colonography protocols for observation of colorectal polyps. Am J Roentgenol. 2006;186:85-89. Excluded for population. [pmid: 16357383].
Yee J, Akerkar GA, Hung RK, Steinauer-Gebauer AM, Wall SD, McQuaid KR. Colorectal neoplasia: performance characteristics of CT colonography for detection in 300 patients. Radiology. 2001;219(3):685-92. Excluded for population. [pmid: 11376255].
Yee J, Kumar NN, Hung RK, Akerkar GA, Kumar PR, Wall SD. Comparison of supine and prone scanning separately and in combination at CT colonography. Radiology. 2003;226:653-661. Excluded for population. [pmid: 12601201].
Yeshwant SC, Summers RM, Yao J, Brickman DS, Choi JR, Pickhardt PJ. Polyps: linear and volumetric measurement at CT colonography. Radiology. 2006;241(3):802-11. Did not report necessary outcomes. [pmid: 17114627].
Yoshinaga M, Motomura S, Takeda H, Yanagisawa Z, Ikeda K. Evaluation of the sensitivity of an immunochemical fecal occult blood test for colorectal neoplasia. American Journal of Gastroenterology. 1995;90(7):1076-9. Excluded for population. [pmid: 7611200].
Young GP, St John DJ, Cole SR, et al. Prescreening evaluation of a brush-based faecal immunochemical test for haemoglobin. Journal of Medical Screening. 2003;10(3):123-8. Excluded for population. [pmid: 14561263].
Young GP, St John DJ, Winawer SJ, Rozen P. Choice of fecal occult blood tests for colorectal cancer screening: recommendations based on performance characteristics in population studies: a WHO (World Health Organization) and OMED (World Organization for Digestive Endoscopy) report. Am J Gastroenterol. 2002;97:2499-2507. Excluded for study design. [pmid: 12385430].
Zappa M, Castiglione G, Paci E, et al. Measuring interval cancers in population-based screening using different assays of fecal occult blood testing: the District of Florence experience. Int J Cancer. 2001;92:151-154. Inadequate application of reference standard. [pmid: 11279619].
Zhu WX, Lin JJ. Reverse passive hemagglutination for detection of fecal occult blood. A comparison with Japanese Immudia-Hem SP Kit. Chin Med J (Engl). 1988;101:519-522. Excluded for population. [pmid: 3147851].

## Characteristics of studies using high sensitivity guaiac fecal occult blood tests or fecal immunochemical tests

Table 4. Characteristics of studies using high sensitivity guaiac fecal occult blood tests or fecal immunochemical tests

Table 4 Characteristics of studies using high sensitivity guaiac fecal occult blood tests or fecal immunochemical tests

Study ID | FIT/High sensitivity | Test Name | Currently available for use in the US? | FDA approved? | Is population a screening or primary care comparable? | Use colonoscopy gold standard? | Did all participants receive gold standard? | Provide Sens/Spec? | | Other Outcomes
Reported | Calculate
Screening populations-all patients receiving colonoscopy
Liu 2003 | FIT (latex agglut) | OC-Hemodia | N | N | Y (perhaps) | Y | Y | Y | | PPV, NPV
Rozen 1997 | FIT; High sensitivity | FlexSure OBT, HemeSelect; HOSensa | N (FlexSure, HemeSelect) Y (HOSensa) | Y | Y (close, only 22% avg risk, but rest were surveillance or FHx) | Y | Y | Y | | PPV, NPV
Nakama 2001 | FIT | Immudia-HemSp | N (same as HemeSelect) | N | Y (likely) | Y | Y | Y | | PPV, NPV
Fattah 1998 | FIT (comb monoclonal ab) | Monohaem | Unknown | Y | Y | Y | Y | Y
Nakama 2004 | FIT (latex agglutination) | OC-Hemodia | N | N | Y | Y | Y | Y
Nakama 1999 | FIT (comb monoclonal ab) | Monohaem | Unknown | Y | Y | Y | Y | Y
Nakama 2000 | FIT | Monohaem | Unknown | Y | Y-likely | Y | Y | N | N | PPV
Nakama 2000 | FIT | Monohaem | Unknown | Y | Y | Y | Y | | Y
Morikawa 2005 | FIT | Magstream | N, but same as HemeSelect which was discontinued | N | Y | Y | Y | Y
Screening populations-only selected patients receive colonoscopy
Castiglione 1994 | FIT; High sensitivity | HemeSelect; HOSensa | N (HemeSelect) Y (HOSensa) | Y | 12.5% sympt | Y | N:+ and high risk | Y- est FN | | PPV
Nakama 1996 | FIT | Monohaem | Unknown | Y | Y | Y | N: + | Y-from F/U | | PPV
Robinson 1994 | FIT | HemeSelect | N | Y | Y | Y or FS, or BE | N: + | Y | | PPV
Zappa 2001 | FOBT, FIT (RPHA) | Hemeselect/Immudia | N (Hemeselect, Immudia) | Y N | Y | Y (or DCBE) | N: + | Y-est
Yamamoto 2000 | FIT (latex agglut inhib) | Iatro-Hemcheck | N | N | Y | Y | N: + | Y
Allison 1996 | High sens, FIT | HOSensa, HemeSelect | Y (HOSensa); N (HemeSelect) | Y | Y | Y (HOS to FS) | N: + HS; +HOS to FS, then colo | Y
Launoy 2005 | FIT | Magstream | N | N | Y | Y | N: + | Y-est | | PPV-estimated
Rennert 2001 | High sensitivity | HOSensa | Y | Y | Y | Y | N: + suggested | Y-est from registry f/u | | PPV
Petrelli 1994 | FIT; High sensitivity | HemeSelect; HOSensa | N (HemeSelect) Y (HOSensa) | Y | Y (very symptomatic-self-selection?) | Y | N | | | PPV
Castiglione 2000 | FIT | Immudia-HemSp, OC-Hemodia | N (ImmSP-same as HemeSelect) | N | Y | Y | N | | | PPV
Levin 1997 | High sensitivity | HOSensa | Y | Y | Y | Y, or FS/BE | N | | | PPV
Hughes 2005 | FIT | Inform (known as InSure) | Y | Y | Y | Y | N | | | PPV
Grazzini 2000 | FIT | Not Reported (OC-Sensor-reported elsewhere) | Y | Y | Y | Y or FS/BE | N | | | PPV
Ciatto 2006 | FIT | OCHemodia | N | N | Y | Y | N | | | PPV
Smith 2006 | FIT; High sensitivity | Insure; HOSensa | Y | Y | Y | Y | N | | | PPV
Robinson 1995 | FIT | HemeSelect | N | Y | Y | Y (or FS/sig/BE) | N | | | PPV
Castiglione 1996 | FIT | HemeSelect | N | Y | Y | Y | N | | | PPV
Guittet 2007 | FIT | Magstream | N | N | Y | Y | N | | | PPV
Chen 1997 | FIT | RPHA | N | N | Y | Y | N | | | PPV
Not screening population- all receive colonoscopy
Rozen 2000 | FIT; High sensitivity | FlexSure OBT; HOSensa | N (FlexSure) Y (HOSensa | Y | N-21% avg; 47% fam hx; 26% surv | Y or FS | N-52% colo; 48% FS w/in 4 yrs | Y | | PPV
Rozen 1995 | FIT; High sensitivity | BM-Test Colon Albumin; HOSensa | N (BMTCA) Y (HOS) | N (BMTCA) Y (HOS) | N (Avg-25; FHx-40; Surv-27) | 59% (FS-41%) | Y | Y
Stelling 1990 | FIT | Monohaem | Unknown | Y (MH) | N | Y | Y | Y | | PPV, NPV
Vironen 2004 | FIT, peanut agglut | Hemolex, PNA | Unknown | Unknown | N | Y | Y | Y
Young 2003 | FIT | Insure; FlexSure OBT | Y (Insure) N (FlexSure OBT) | Y | N | Y | Y | Y
Greenberg 2000 | FIT; High sensitivity | FlexSure OBT, HemeSelect; HOSensa | N (FlexSure, HemeSelect) Y (HOSensa) | Y | N | Y | Y | Y
Li 2006 | FIT | Hemosure | Y | Y | N | Y | Y | Y
Nakama 1998 | FIT | Hemcheck | Unknown | N | N | Y | Y | Y
Hope 1996 | FIT | Monohaem, BM-Test Colon Albumin | Unknown (MH) N (BMTCA) | Y(MH) N | N | Y | Y | Y
Yoshinaga 1995 | FIT | OC-Hemodia | N | N | N | Y | Y | Y
Iida 1995 | FIT | OC-Hemodia | N | N | N | Y or BE | Y | Y
Gopalswamy 1994 | FIT; High sensitivity | HemeSelect, Monohaem, FECA-EIA; Coloscreen, HOSensa | Y (HOS) N (HS, FECA) Unknown (MH) | Y (HS, MH, HOS) | N | Y (BE 7%) | Y | Y | | PPV, NPV
Woo 2005 | 3 × FIT (anti-globin × 2, latex agglut) | Occultech, Instant-view, HM-Jack | Y (Occultech and Instant-view are now Quickvue); N (HM-Jack) | Y (Occu; InsView) N(HMJ) | N | Y | Y | Y | | PPV
Levi 2006 | FIT (latex agglut) | OC-Micro | Y | Y | N | Y | Y | Y | | PPV, NPV
Nakama 2000 | 5 × FIT (RPHA, comb monoclonal Ab, latex agglut inhib, latex agglut) | Immudia-Hemsp, Monohaem, Iatro Hemcheck, LA Hemochaser, OC-Hemodia | Unknown (MH) N | Y (MH) N (others) | N | Y | Y | Y
Nakama 1998 | 5 × FIT (RPHA, comb monoclonal Ab, latex agglut inhib, latex agglut) | Immudia-Hemsp, Monohaem, Iatro Hemcheck, LA Hemochaser, OC-Hemodia | Unknown (MH) N | Y (MH) N (others) | N | Y | Y | Y
Fattah 1997 | FIT (comb monoclonal ab) | Monohaem | Unknown | Y | N | Y | Y | | Y
Nakama 1997 | FIT (latex agglut) | OC-Hemodia | N | N | N | Y | Y | | Y
Fraser 2006 | FIT (anti-human globin) | Instant-View | Y (Quickvue) | Y | N | Y | Y | Y
Jeanson 1994 | FIT | Hemoblot | N | N | N | Y | Y | Y
Fraser 2007 | FIT | Not Reported | | | N | Y | Y | Y | | T +/- LR
Levi 2007 | FIT | OC-Micro | Y | Y | N | Y | Y | Y | | PPV, LR
Wong 2003 | FIT; High sensitivity | FlexSure OBT; HOSensa | N (FlexSure) Y (HOSensa) | Y | N | Y | Y | Y | | PPV
Saitoh 2000 | FIT | LA hemochaser | Unknown | N | N | Y | Y | Y
Miyoshi 2000 | FIT | Immudia-HemSp, OC-hemodia, Immunohemostick | N | N | N | Y | Y | Y
Vilkin 2005 | FIT | OC-Sensor | Unknown | N | N | Y | Y | Y
Hoepffner 2006 | FIT; High sensitivity | Prevent ID CC | Unknown | N | N | Y | Y | Y
Not screening population-not all receiving colonoscopy
Fattah 1997 | FIT | Monohaem | Unknown | Y | N | Y | N | Y
Levi 2006 | FIT; High sensitivity | OC-Micro; HOSensa | Y | Y | N | Y | N | Y | | PPV
Nakama 1999 | FIT (comb monoclonal ab) | Monohaem | Unknown | Y | N | Y (4% DCBE instead) | N | N | | PPV
James 1992 | FIT | HemoQuant | N | N | N | Y | N | Y

## List of Fecal Immunochemical Tests

Table 5. List of Fecal Immunochemical Tests

Table 5 List of Fecal Immunochemical Tests

Test | Marketed in US | FDA approved
Monohaem | unknown | yes
Insure and Inform same test | yes | yes
HemeSelect | no | yes
Magstream-currently used in Australia | no | no
Immundia-HemSP-Japan | no | no
OC-Sensor | no | no
OC-Micro-same as OC Sensor | unknown | yes
OC-Hemodia-test for OC-Sensor | no | no
FlexSure OBT-now Hemoccult-ICT | yes | yes
BM-Test Colon Albumin | no | no
Prevent ID CC | unknown | unknown
Diagnostik | unknown | unknown
Occultech and Instant-view are now Quickvue | yes | yes
HM-Jack | no | no
LA Hemochaser | unknown | no
Hemosure | yes | yes
Feca EIA | no | no