# Appendix C. Study Details KQ2a

## Flexible Sigmoidoscopy

Estimated adenoma and carcinoma miss rates for flexible sigmoidoscopy within the distal colon. In a good-quality prospective cohort study by Schoen et al.,{Schoen, 2003 1414 /id} investigators performed repeat flexible sigmoidoscopy (FS) on 9,317 patients with a previously negative FS three years earlier. Subjects were among those aged 55–74 recruited for a large multicenter cancer screening trial, the Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial. The 9,317 patients comprised 80.4 percent of the original sample with a negative initial flexible sigmoidoscopy. All patients were asymptomatic and were examined for CRC screening, although 10.1 percent of patients had a single first degree relative with a history of CRC; 86.7 percent of patients were Caucasian and 38.4 percent were female, with a mean age of 65.7 years. Diagnostic followup was completed in 951 (73.6 percent) of the 1,292 individuals with an abnormal finding at the year-three screening sigmoidoscopy. The prevalence of distal advanced adenoma or cancer at 3 years followup was found to be 78 out of 9,317 persons, resulting in an approximate miss rate for advanced neoplasia in the distal colon of 0.8 percent of persons with an initial negative FS. A depth of penetration of greater than 60 cm in more than 63 percent of initial FS examinations suggests that the quality of initial examinations was high overall.

Burke et al. ^143^ also examined the prevalence of distal adenomas and cancers in an asymptomatic screening cohort using a subgroup that agreed to followup FS exam 3 years after the negative FS examinations. Nine hundred and fifteen asymptomatic patients agreed to undergo the second FS. The authors did not report what proportion of the initial examinees declined the second test. Attending gastroenterologists at the Cleveland Clinic conducted all of the examinations. The status of family history was not reported. The median depth of examination for the first examination was 35 cm and 45 cm for the second examination. The mean age of patients was 54 years, and 36 percent of patients were female. After 3 years of follow-up, 8 of the 915 patients (0.87 percent) had an advanced neoplasia on exam, including 1 patient with invasive carcinoma. All of the advanced neoplastic lesions were in locations within reach of the initial flexible sigmoidoscopy exam, so the less-than-optimal initial examinations did not impact the overall miss rates in this study.

A fair-quality tandem FS study by Schoenfeld et al. ^141^ examined the comparative miss rates for adenomatous polyps for three trained nurse endoscopists, compared with six trained physician endoscopists, among all patients attending for screening FS within a five-month period. Three hundred and thirteen patients were enrolled to receive their first FS by either a nurse or physician, with a tandem, same-day follow-up FS by the other type of clinician, who was masked as to the first FS findings. Patients were 34 percent female and had a mean age of 60 years. Risk status and other sociodemographic characteristics were not reported. A total of 43 people (13.7 percent) had at least one adenoma identified on baseline FS and 6 people with no adenoma on first FS had one or more adenomas found on second FS. The proportion of patients who had adenomas identified only on the second exam was 3 percent (4/126) for the physicians and 3 percent (2/123) for the nurses. The adenoma miss rate for physicians was 20 percent (6/30), and for nurses was 21 percent (3/14). Neither physicians nor nurses missed any adenoma greater than one centimeter diameter. Average insertion depth for the sigmoidoscope was further for physicians, as compared to nurses (mean depth 61 cm vs. 55 cm, p< 0.05) and there were no complications reported. Insertion to 35 cm or less was associated with missing descending colon polyps. The study's major limitation was the high attrition rate of 20 percent (64/313), primarily due to voluntary withdrawal after the first exam and secondarily to incomplete endoscopy from excess retained stool. As well, the use of magnesium citrate, an oral laxative, for bowel preparation is more than the enemas usually used for flexible sigmoidoscopy. Above-average bowel cleansing in this study suggests this is an underestimation of true community miss rates.

Sensitivity of FS protocols for advanced neoplasia or CRC, based on distal findings: Screening colonoscopy studies. To estimate the diagnostic utility of distal colonic polyps, Betes et .al. ^144^ retrospectively reviewed results in 2210 average-risk patients (mean age 57.9 years, 25 percent female, all without a family or personal history of CRC) who participated in a university-based colonoscopy screening program in Spain from 1988 through 1998. In all those screened, there were 56 proximal advanced neoplasms (PAN) (2.5 percent). This number, and subsequent evaluations, is affected when the definition of distal includes the rectum, descending, and sigmoid colons. Most (73.1 percent) persons screened (1616/2210) had no findings, or only hyperplastic polyps or benign polyps, in the distal colon; 5.4 percent had advanced neoplasia (n=119); 15.0 percent had nonadvanced adenomas (n=331); and several (6.5 percent) had diminutive polyps (n=144) in the distal colon. While the prevalence of PAN in those with no distal findings was low (1.4 percent; 22/1616), 39.3 percent of all PAN lesions were in those with no distal lesions. Prevalence of PAN was highest (16.0 percent) in those with distal advanced neoplasia (n=119), less common (4.3 percent) in those with non-advanced distal adenomas (n=331), and rare (0.7 percent) in those with diminuitive polyps. Sensitivity of the FS with biopsy protocol was calculated to be 85.3% for advanced neoplasia in the whole colon. Data for calculating other sensitivity estimates was not available.

Ikeda and colleagues ^145^ retrospectively evaluated screening colonoscopies in 3131 Japanese average risk, asymptomatic men conducted as part of a pre-retirement health evaluation program—after excluding those with hyperplastic polyps alone (n=197). Among the 3131 participants, 812 men (26 percent) had a total of 1231 neoplastic lesions (18 CRC, 1213 adenomas). Almost half (44 percent) of adenomas were proximal. The distal colon was again defined as including the rectum, sigmoid and descending colon. Among all 3131 men with colonoscopy, the prevalence of small proximal tubular adenomas was 12.0 percent, of advanced proximal neoplasia was 0.9 percent, and of CRC was 0.1 percent. In those with no distal lesions, 10.7 percent had small proximal tubular adenomas, while 0.8 percent had advanced small proximal tubular adenomas. Prevalence of proximal adenomas was similar in those with small distal adenomas (less than 10 mm) compared with advanced distal neoplasia. Risk of PAN was much higher (6.0 percent), however, in those with advanced neoplasia compared with small adenomas (1.3 percent). Sensitivity of the FS with biopsy protocol was calculated to be 73.7% for advanced neoplasia in the whole colon. Data for calculating other sensitivity estimates was not available.

Anderson et al. ^58^ conducted a retrospective review of 1,988 charts from screening colonoscopies in average-risk patients referred to a university screening clinic in Stony Brook, New York. The authors evaluated the association of isolated proximal neoplasia in this cohort with other demographic factors recorded in their charts, including age, BMI, gender, family history of colorectal cancer, smoking status, education, aspirin use, ethnicity, alcohol use, exercise habits, and fruit/vegetable intake. Patients with gastrointestinal symptoms, prior history of colonic disease, or an endoscopic exam during the previous 10 years were excluded from the study. Overall prevalence of advanced neoplasia in the colon was 10.2 percent. The prevalence of isolated PAN was 3.2 percent, given the definition of the distal colon as including the descending and sigmoid colon and rectum. The odds of having any colorectal neoplasia for those over age of 60 were more than twice that of those 60 and younger (OR 2.34; 1.79, 3.05; P<0.001). The prevalence of isolated PAN also increased with age: 0.9 percent for age <49, 2.0 percent for those age 50 to 59 years, 4.1 percent for those age 60 to 69 years, and 5.4 percent for those age >70 years. The odds of having any colorectal neoplasia for current smokers were nearly twice the odds for those who had never smoked (OR 1.89; 1.42, 2.52; P<0.001). Family history and gender were also associated with a statistically significant increased risk of colorectal neoplasia. Sensitivity of the FS with biopsy protocol was 73.8% for advanced neoplasia and 62.5% for CRC in the whole colon.

Imperiale et.al. ^146^ conducted a similar retrospective analysis of 3025 screening colonoscopies in average-risk, asymptomatic, primarily (90 percent) white, middle-to-upper SES adults over aged years (1753 in men and 1272 in women) who were part of a workplace-based screening program. These data provide detailed information on risk for PAN by age and sex. Overall, 2.7 percent of all those screened had PAN, with higher percentages in men (3.9 percent) than women (1.2 percent). Risk increased with 5-year age increments (from 0.8 percent in persons 50 to 54 years to 5.6 percent in those 65 years and older). Due to a threefold greater risk of PAN in men than women, the absolute risk of PAN by age varied between men and women. For women under age 65, the absolute risk of PAN did not exceed 1.0 percent, while the absolute risk of PAN was 3.5 percent or greater in men beginning at age 55 years. Risk for PAN was above 5.0 percent in men and women with any distal adenomas (regardless of size or histology). Sensitivity for FS with biopsy protocol was 71.8% for advanced neoplasia in the whole colon. Sensitivity of the FS without biopsy protocol was slightly higher, 76.8% for advanced neoplasia in the whole colon. A study ^59^ of the earliest members of the same cohort reported histology and size of polyps on screening colonoscopy in 1994 patients. The sensitivity of the FS with biopsy protocol for CRC in the whole colon 58.3% (7/12), and of the FS without biopsy protocol was 75.0% (8/12) for CRC in the whole colon.

Lieberman et al. ^60^ conducted a prospective study of screening colonoscopy in 3,121 asymptomatic veteran males, aged 50–75 years and primarily white (83.6 percent). Patients were recruited from 13 Veterans Affairs medical centers from major cities in the United States and were asymptomatic, with no major comorbidities, no history of colorectal disease, and no previous colon examination within the preceding 10 years. Of the study population, 13.9% had a family history of colorectal cancer in at least one first-degree relative. Overall, 10.5 percent of patients had advanced neoplasms in the colon. The patients with distal hyperplastic polyps did not have a higher risk of advanced proximal neoplasia than the patients without any distal polyps. The prevalence of PAN was greater for those with distal non-advanced adenomas (6.8 percent), and greater yet for those with distal advanced adenomas (11.4 percent). The prevalence of PAN increased with age (P<0.001), from 2 percent for patients 50 to 59 years old, to 4.9 percent for those 60 to 69 years old, to 5.9 percent for those 70 to 75 years old. The overall prevalence of PAN was higher (5.4 percent) when the distal colon was designated as including only the rectum and sigmoid colon (and not the descending colon, as above—3.9 percent). Two sets of estimates of sensitivity were available and were based on differing definitions of the distal colon. With the distal colon including the descending colon (Definition 1), sensitivity estimates were higher than for the inclusion of the rectum and sigmoid colon only (Definition 2). For the more inclusive definition of the distal colon, Definition 1 (which mirrors the results of the above studies), sensitivity of the FS with biopsy protocol was 81.7% for advanced neoplasia in the whole colon. Sensitivity of the FS without biopsy protocol is slightly higher, 85.6% for advanced neoplasia in the whole colon. For the less inclusive (and more conservative) definition of the distal colon, Definition 2, sensitivity of the FS with biopsy protocol was 71.2% for advanced neoplasia in the whole colon. Sensitivity of the FS without biopsy protocol is slightly higher, 78.7% for advanced neoplasia in the whole colon.

Schoenfeld et al. ^61^ conducted a prospective study of screening colonoscopy in veteran women as a comparative study to that conducted by Lieberman et al. Colonoscopy was completed in 1,463 women aged 40–79 years, 15.7 percent of whom had a family history of CRC in a first-degree relative. Patients with gastrointestinal symptoms, a history of colon disease, a previous flexible sigmoidoscopy within 5 years, a previous colonoscopy within 10 years, or a positive FOBT test within 1 year were excluded. The prevalence of advanced neoplasms in the colon overall was 4.9 percent. This prevalence varied significantly by age: 3.3 percent in those 50 to 59 years of age, 5.5 percent in those 60 to 69 years of age, and 11.7 percent of women who were 70 to 79 years of age. The prevalence of isolated proximal advanced neoplasia was 3.2 percent. The sensitivity of distal colon findings for advanced neoplasia is much lower than for other studies at 34.7 percent. As in Lieberman's study, the authors provide two sets of sensitivity estimates based on different definitions of the distal colon. For the more inclusive definition of the distal colon, Definition 1 (which mirrors the results of the other studies), sensitivity of the FS with biopsy protocol is 50.0% for advanced neoplasia in the whole colon. For the less inclusive (and more conservative) definition of the distal colon, Definition 2, sensitivity of the FS with biopsy protocol is 34.7% for advanced neoplasia in the whole colon.

## KQ2A sensitivity of colonoscopy evidence table

Table 1 KQ2A sensitivity of colonoscopy evidence table

Study | Setting Targeted Population | Reference/Gold Standard | Inclusion / Exclusion Criteria | Patient Characteristics
Pickhardt 2003 ^136^ Good | 3 US medical centers Recruited consecutive patients who were primarily referred for screening colonoscopy | OC with segmental unblinding to CTC; applied to 100% of patients. Seventeen experienced colonoscopists (14 gastroenterologists, 3 colorectal surgeons) Six experienced radiologists (minimum 25 CTC readings, two of the six had >100 CTC readings) | Inclusion: Asymptomatic adults age 50 to 79 years of average risk, age 40 to 79 years with family history, referred for CRC screening Exclusion: Positive FOBT result or iron deficiency anemia within the past 6 months; rectal bleeding or hematochezia or unintentional weight loss within the past 12 months; colonoscopy within the past 10 years; barium enema within the past 5 years; personal history of adenomatous polyps, CRC or IBD; family history of FAP or nonpolyposis cancer syndromes; rejection for colonoscopy for any reason; medical condition that precludes use of sodium phosphate prep; pregnancy | N: 1233 (1253 enrolled) Age, mean: 57.8 yrs Female: 41% Ethnicity: NR SES: NR % with Risk Factors: 2.6% with family history of CRC
Kim 2007 ^137^ Fair | Korea Retrospective analysis to compare 2D and 3D interpretation of CTC | OC with segmental unblinding to CTC; applied to 100% of patients Five experienced gastroenterologists(7–15 years experience) Two experienced radiologists (100 CTC readings) | Inclusion: NR Exclusion: Prior colorectal surgery; IBD; iron deficiency anemia or positive FOBT results within the past 6 months; age <40 years; history FAP; history of polypectomy within past year | N: 96 Age, mean: 54.8 yrs Female: 42% Ethnicity: 100% Asian (assumed) SES: NR
Johnson 2007 ^138^ Fair | Mayo Clinic, MN Prospective analysis to compare 2D and 3D interpretation of CTC | Videotaped OC with selective repeat colonoscopy (n=6) if comparison with CTC had lesions ≥ 10mm after re-review by radiologists and determined to have a high likelihood of being a true neoplasm Staff gastroenterologists, or were supervised by one of approximately 50 experienced staff gastroenterologists and colorectal surgeons Three experience radiologists (>1000 CTC reads) | Inclusion: Asymptomatic, ≥40 years old, scheduled to undergo screening colonoscopy Exclusion: Melena, hematochezia, IBD, familial polyposis, or symptomatic | N: 452 Age, mean: 65 yrs Female: 44% Ethnicity: White 85% Asian 12% Hispanic 3% African American 1% Native American 0.2% SES: NR
Pickhardt 2003 ^136^ Good | Polyps (all) # total polyps: 1310 # polyps ≥6 mm: 344 # polyps ≥10 mm: 82 Polyps (adenomatous) # total polyps: 554 # polyps ≥6 mm: 210 # polyps ≥10 mm: 51 | [underlined: Sensitivity per polyp (adenomatous), [95%CI]:] ≥ 6 mm: 90.0% (189/210), [85.1, 93.7] ≥ 8 mm: 89.5% (85/95), [81.5, 94.8] ≥10 mm: 88.2% (45/51), [76.1, 95.6] [underlined: Miss rate per polyp (adenomatous) (c):] ≥ 6 mm: 10.0% (21/210) ≥ 8 mm: 10.5% (10/95) ≥10 mm: 11.8% (6/51) [underlined: Sensitivity for adenoma per person, [95%CI]:] ≥ 6 mm: 92.3% (155/168), [87.1, 95.8] ≥ 8 mm: 91.5% (75/82), [83.2, 96.5] ≥10 mm: 87.5% (42/48), [74.8, 95.3] [underlined: Miss rate for adenoma per person (c):] ≥ 6 mm: 7.7% (13/168) ≥ 8 mm: 8.5% (7/82) ≥ 10 mm: 12.5% (6/48) | Colonoscopists may be more experienced than in the community setting | 20 patients excluded (8 had incomplete colonoscopy, 6 had inadequate prep, 6 had failure of CTC system) Standard bowel prep, and fecal tagging with oral contrast for CTC, type of sedation NR Only 2 CRC detected, one of the two was missed by colonoscopy
Kim 2007 ^137^ Fair | Polyps (all) # total polyps: 134 # polyps ≥6 mm: 35 # polyps ≥10 mm: 12 Polyps (adenomatous) # total polyps: 61 # polyps ≥6 mm: 22 # polyps ≥10 mm: 8 | [underlined: Sensitivity per polyp (adenomatous), [95%CI]:] ≥ 6 mm: 93.4% (57/61), [NR] ≥ 8 mm: NR ≥10 mm: NR [underlined: Miss rate per polyp (adenomatous) (c):] ≥ 6 mm: 6.6% (4/61) [underlined: Sensitivity and miss rate per person:] NR | Full patient descriptions not available-although some high risk populations were clearly excluded. Generalizability to the US population is unknown. | Standard bowel prep, no fecal tagging, conscious sedation with midazolam No CRC detected
Johnson 2007 ^138^ Fair | Polyps (all) # total polyps: NR # polyps ≥6 mm: 93 # polyps ≥10 mm: 43 Polyps (neoplastic) # total polyps: NR # polyps ≥6 mm: 64 # polyps ≥10 mm: 26 | [underlined: Sensitivity per neoplastic polyp, [95%CI]:] ≥ 6 mm: NR ≥ 8 mm: NR ≥10 mm: 76.9% (20/26), [NR] [underlined: Miss rate per neoplastic polyp (c):] ≥10 mm: 23.1% (6/26) [underlined: Sensitivity and miss rate per person:] NR | Asymptomatic population but did include persons with previous colonic resection | Six patients with incomplete colonoscopy Variable bowel prep (at the discretion of referring physician), no fecal tagging with oral contrast, type of sedation NR Did not use segmental unblinding Only five CRC detected, 4 of the 5 CRC missed by colonoscopy

## Table 2. Key question 2A excluded studies

### Reference Reason for exclusion

Allison JE. Colon Cancer Screening Guidelines 2005: the fecal occult blood test option has become a better FIT. Gastroenterology. 2005;129:745-748. Excluded study design. [pmid: 16083728].
Avidan B, Sonnenberg A, Schnell TG, Leya J, Metz A, Sontag SJ. New occurrence and recurrence of neoplasms within 5 years of a screening colonoscopy. American Journal of Gastroenterology 97(6):1524 Excluded for incorrect population
Barclay RL, Vicari JJ, Doughty AS, Johanson JF, Greenlaw RL. Colonoscopic withdrawal times and adenoma detection during screening colonoscopy. N Engl J Med. 2006;355:2533-2541. Excluded study design. [pmid: 17167136].
Bianco MA, Rotondano G, Marmo R, et al. Predictive value of magnification chromoendoscopy for diagnosing invasive neoplasia in nonpolypoid colorectal lesions and stratifying patients for endoscopic resection or surgery. Endoscopy. 2006;38(5):470-6. Excluded for study relevance. [pmid: 16767581].
Bressler B, Paszat LF, Chen Z, Rothwell DM, Vinden C, Rabeneck L. Rates of new or missed colorectal cancers after colonoscopy and their risk factors: a population-based analysis. Gastroenterology. 2007;132:96-102. Excluded for study design. [pmid: 17241863].
Chen SC, Rex DK. Endoscopist Can Be More Powerful than Age and Male Gender in Predicting Adenoma Detection at Colonoscopy. Am J Gastroenterol. 2007. Excluded study design
Citarda F, Tomaselli G, Capocaccia R, Barcherini S, Crespi M. Efficacy in standard clinical practice of colonoscopic polypectomy in reducing colorectal cancer incidence. Gut. 2001;48:812-815. Excluded for study relevance. [pmid: 11358901].
Deenadayalu VP, Chadalawada V, Rex DK. 170 degrees wide-angle colonoscope: effect on efficiency and miss rates. Am J Gastroenterol. 2004;99:2138-2142. Excluded population. [pmid: 15554993].
Doria-Rose VP, Levin TR, Selby JV, Newcomb PA, Richert-Boe KE, Weiss NS. The incidence of colorectal cancer following a negative screening sigmoidoscopy: implications for screening interval.[see comment]. Gastroenterology. 2004;127:714-722. Did not report relevant outcomes. [pmid: 15362026].
Halligan S, Atkin W. Unbiased studies are needed before virtual colonoscopy can be dismissed. Lancet. 2005;365:275-276. Excluded study design. [pmid: 15664205].
Harewood GC. What is the most sensitive screening method for the detection of colon cancer?. Nature Clinical Practice Gastroenterology & Hepatology. 2005;2(3):134-5. Excluded study design.
Harrison M, Singh N, Rex DK. Impact of proximal colon retroflexion on adenoma miss rates. Am J Gastroenterol. 2004;99:519-522. Excluded population. [pmid: 15056095].
Hixson LJ, Fennerty MB, Sampliner RE, Garewal HS. Prospective blinded trial of the colonoscopic miss-rate of large colorectal polyps. Gastrointest Endosc. 1991;37:125-127. Excluded for incorrect population. [pmid: 2032595].
Hixson LJ, Fennerty MB, Sampliner RE, McGee D, Garewal H. Prospective study of the frequency and size distribution of polyps missed by colonoscopy. J Natl Cancer Inst. 1990;82:1769-1772. Excluded setting. [pmid: 2231773].
Ho, C., Jacobs, P., Sandha, G., Noorani, H. Z., and Skidmore, B. Non-physicians performing screening flexible sigmoidoscopy: clinical efficacy and cost-effectiveness. 2006. Ottawa: Canadian Coordinating Office for Health Technology Assessment (CCOHTA). Did not report necessary outcomes
Hoff G, Thiis-Evensen E, Grotmol T, Sauar J, Vatn MH, Moen IE. Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983-1996. Eur J Cancer Prev. 2001;10:131-137. Excluded for study relevance. [pmid: 11330453].
Hosokawa O, Shirasaki S, Kaizaki Y, Hayashi H, Douden K, Hattori M. Invasive colorectal cancer detected up to 3 years after a colonoscopy negative for cancer. Endoscopy. 2003;35:506-510. Excluded study design. [pmid: 12783349].
Hurlstone DP, Sanders DS. Recent advances in chromoscopic colonoscopy and endomicroscopy. Current Gastroenterology Reports. 2006;8(5):409-15. Excluded for study design. [pmid: 16968609].
Kato S, Fujii T, Koba I, et al. Assessment of colorectal lesions using magnifying colonoscopy and mucosal dye spraying: can significant lesions be distinguished?. Endoscopy. 2001;33:306-310. Excluded for study relevance. [pmid: 11315890].
Kavanagh AM, Giovannucci EL, Fuchs CS, Colditz GA. Screening endoscopy and risk of colorectal cancer in United States men. Cancer Causes Control. 1998;9:455-462. Excluded for study relevance. [pmid: 9794179].
Kiesslich R, von BM, Hahn M, Hermann G, Jung M. Chromoendoscopy with indigocarmine improves the detection of adenomatous and nonadenomatous lesions in the colon. Endoscopy. 2001;33:1001-1006. Excluded for study relevance. [pmid: 11740641].
Leaper M, Johnston MJ, Barclay M, Dobbs BR, Frizelle FA. Reasons for failure to diagnose colorectal carcinoma at colonoscopy. Endoscopy. 2004;36:499-503. Excluded for study design. [pmid: 15202045].
Levin TR, Farraye FA, Schoen RE, et al. Quality in the technical performance of screening flexible sigmoidoscopy: recommendations of an international multi-society task group. Gut. 2005;54:807-813. Excluded study design. [pmid: 15888789].
Levin TR, Palitz A, Grossman S, et al. Predicting advanced proximal colonic neoplasia with screening sigmoidoscopy. JAMA. 1999;281:1611-1617. Excluded study design. [pmid: 10235154].
Levin TR. What does sigmoidoscopy really miss?. American Journal of Gastroenterology. 2003;98(10):2326-7. Excluded study design. [pmid: 14572589].
Lewis JD, Ng K, Hung KE, et al. Detection of proximal adenomatous polyps with screening sigmoidoscopy: a systematic review and meta-analysis of screening colonoscopy. Archives of Internal Medicine. 2003;163(4):413-20. Excluded study design. [pmid: 12588199].
Lieberman DA, Weiss DG, Harford WV, et al. Five-year colon surveillance after screening colonoscopy. Gastroenterology. 2007;133:1077-1085. Did not report relevant outcomes. [pmid: 17698067].
Lieberman DA, Weiss DG. Veterans Affairs Cooperative Study Group. One-time screening for colorectal cancer with combined fecal occult-blood testing and examination of the distal colon. New England Journal of Medicine. 2001;345(8):555-60. Excluded setting. [pmid: 11529208].
Luchtefeld MA, Kim DG. Colonoscopy in the office setting is safe, and financially sound ... for now. Diseases of the Colon & Rectum. discussion 381 –2. 2006;49(3):377-81. Excluded for study relevance. [pmid: 16475034].
Matsushita M, Takakuwa H, Matsubayashi Y, Nishio A, Ikehara S, Okazaki K. Appendix is a priming site in the development of ulcerative colitis. World Journal of Gastroenterology. 2005;11:4869-4874. Excluded setting. [pmid: 16097061].
McCallion K, Mitchell RM, Wilson RH, et al. Flexible sigmoidoscopy and the changing distribution of colorectal cancer: implications for screening. Gut. 2001;48(4):522-5. Excluded study design. [pmid: 11247897].
Menardo G. Sensitivity of diagnostic examinations for colorectal polyps. Techniques in Coloproctology. 2004;8(Suppl 2):s273-5. Excluded study design. [pmid: 15666105].
Muller AD, Sonnenberg A. Protection by endoscopy against death from colorectal cancer. A case-control study among veterans. Arch Intern Med. 1995;155:1741-1748. Did not report necessary outcomes. [pmid: 7654107].
Neugut AI, Jacobson JS, Ahsan H, et al. Incidence and recurrence rates of colorectal adenomas: a prospective study. Gastroenterology. 1995;108:402-408. Excluded for study quality. [pmid: 7835580].
Newcomb PA, Norfleet RG, Storer BE, Surawicz TS, Marcus PM. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84:1572-1575. Excluded for study relevance. [pmid: 1404450].
Nicholson FB, Korman MG, Stern AI, Hansky J. Distribution of colorectal adenomas: implications for bowel cancer screening. Med J Aust. 2000;172:428-430. Excluded population. [pmid: 10870535].
Phillips KA, Liang SY, Ladabaum U, et al. Trends in colonoscopy for colorectal cancer screening. Med Care. 2007;45:160-167. Excluded for study relevance. [pmid: 17224779].
Pickhardt PJ, Nugent PA, Mysliwiec PA, Choi JR, Schindler WR. Location of adenomas missed by optical colonoscopy. Annals of Internal Medicine. 2004;141(5):352-9. Excluded study design. [pmid: 15353426].
Postic G, Lewin D, Bickerstaff C, Wallace MB. Colonoscopic miss rates determined by direct comparison of colonoscopy with colon resection specimens. Am J Gastroenterol. 2002;97:3182-3185. Excluded for study quality. [pmid: 12492208].
Rasmussen M, Kronborg O, Fenger C, Jorgensen OD. Possible advantages and drawbacks of adding flexible sigmoidoscopy to hemoccult-II in screening for colorectal cancer. A randomized study. Scandinavian Journal of Gastroenterology. 1999;34(1):73-8. Excluded for study relevance. [pmid: 10048736].
Rex DK, Chadalawada V, Helper DJ. Wide angle colonoscopy with a prototype instrument: impact on miss rates and efficiency as determined by back-to-back colonoscopies. Am J Gastroenterol. 2003;98:2000-2005. Did not include one of the specific screening tests. [pmid: 14499778].
Rex DK, Cummings OW, Helper DJ, et al. 5-year incidence of adenomas after negative colonoscopy in asymptomatic average-risk persons [see comment]. Gastroenterology. 1996;111:1178-1181. Excluded for study design. [pmid: 8898630].
Rex DK, Cutler CS, Lemmel GT, et al. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. 1997;112:24-28. Excluded population. [pmid: 8978338].
Rex DK, Rahmani EY, Haseman JH, Lemmel GT, Kaster S, Buckley JS. Relative sensitivity of colonoscopy and barium enema for detection of colorectal cancer in clinical practice. Gastroenterology. 1997;112:17-23. Excluded population. [pmid: 8978337].
Rex DK. Colonoscopic withdrawal technique is associated with adenoma miss rates. Gastrointest Endosc. 2000;51:33-36. Excluded for study relevance. [pmid: 10625792].
Rex DK. Colonoscopy practice variation. Gastrointest Endosc. 2003;58:639-640. Excluded population. [pmid: 14520310].
Rex DK. Maximizing detection of adenomas and cancers during colonoscopy. American Journal of Gastroenterology. 2006;101(12):2866-77. Excluded study design. [pmid: 17227527].
Rockey DC, Paulson E, Niedzwiecki D, et al. Analysis of air contrast barium enema, computed tomographic colonography, and colonoscopy: prospective comparison. Lancet. 2005;365:305-311. Excluded population. [pmid: 15664225].
Sawhney MS, Farrar WD, Gudiseva S, et al. Microsatellite instability in interval colon cancers. Gastroenterology. 2006;131(6):1700-5. Excluded for study design. [pmid: 17087932].
Schoen RE, Weissfeld JL, Pinsky PF, Riley T. Yield of advanced adenoma and cancer based on polyp size detected at screening flexible sigmoidoscopy. Gastroenterology. 2006;131(6):1683-9. Excluded for study relevance. [pmid: 17188959].
Selby JV, Friedman GD, Quesenberry CP Jr, Weiss NS. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-657. Did not report necessary outcomes. [pmid: 1736103].
Senore C, Segnan N, Bonelli L, et al. Predicting proximal advanced neoplasms at screening sigmoidoscopy. Diseases of the Colon & Rectum. 2004;47(8):1331-40. Excluded population. [pmid: 15484347].
Shapero TF, Hoover J, Paszat LF et al. Colorectal cancer screening with nurse-performed flexible sigmoidoscopy: results from a Canadian community-based program. Gastrointest Endosc. 2006. Excluded study design
Singh H, Turner D, Xue L, Targownik LE, Bernstein CN. Risk of developing colorectal cancer following a negative colonoscopy examination: evidence for a 10-year interval between colonoscopies. JAMA. 2006;295(20):2366-73. Excluded population. [pmid: 16720822].
Sonwalkar S, Rotimi O, Rembacken BJ. Characterization of colonic polyps at conventional (nonmagnifying) colonoscopy after spraying with 0.2 % indigo carmine dye. Endoscopy. 2006;38:1218-1223. Excluded for study relevance. [pmid: 17163322].
Stergiou N, Frenz MB, Menke D, Riphaus A, Wehrmann T. Reduction of miss rates of colonic adenomas by zoom chromoendoscopy. International Journal of Colorectal Disease. 2006;21(6):560-5. Excluded for incorrect population. [pmid: 16283340].
Thiis-Evensen E, Hoff GS, Sauar J, Langmark F, Majak BM, Vatn MH. Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. 1999;34:414-420. Excluded for study relevance. [pmid: 10365903].
Thomas-Gibson S, Thapar C, Shah SG, Saunders BP. Colonoscopy at a combined district general hospital and specialist endoscopy unit: lessons from 505 consecutive examinations. J R Soc Med. 2002;95:194-197. Did not report necessary outcomes. [pmid: 11934910].
Thomson J, Phull P. Audit of bowel preparation with Picolax (sodium picosulfate plus magnesium citrate) for colonoscopy. Int J Clin Pract. 2006;60:602-603. Did not report necessary outcomes. [pmid: 16700862].
van Rijn JC, Reitsma JB, Stoker J, Bossuyt PM, van Deventer SJ, Dekker E. Polyp miss rate determined by tandem colonoscopy: a systematic review. Am J Gastroenterol. 2006;101:343-350. Excluded population. [pmid: 16454841].
Winawer SJ, Zauber AG, O'Brien MJ, et al. Randomized comparison of surveillance intervals after colonoscopic removal of newly diagnosed adenomatous polyps. The National Polyp Study Workgroup. N Engl J Med. 1993;328:901-906. Excluded study design. [pmid: 8446136].

## Studies estimating sensitivity of flexible sigmoidoscopy

Table 3 Studies estimating sensitivity of flexible sigmoidoscopy

Study | Patient characteristics | Overall polyp prevalence | Prevalence of patients with proximal neoplasia | Prevalence of patients with proximal advanced neoplasia by FS findings | | | Sensitivity of FS with biopsy for advanced neoplasia in the whole colon | Sensitivity of FS without biopsy for advanced neoplasia in the whole colon | Sensitivity of FS with biopsy for CRC in the whole colon | Sensitivity of FS without biopsy for CRC in the whole colon
Study | Patient characteristics | Overall polyp prevalence | Prevalence of patients with proximal neoplasia | Among all with no distal lesions | Among all with distal polyps or adenomas | | Sensitivity of FS with biopsy for advanced neoplasia in the whole colon | Sensitivity of FS without biopsy for advanced neoplasia in the whole colon | Sensitivity of FS with biopsy for CRC in the whole colon | Sensitivity of FS without biopsy for CRC in the whole colon
Non-advanced adenoma | Advanced adenoma
Betes Ibanez 2004 ^144^ Spain Distal definition: descending & sigmoid colon, rectum | N: 2,210 Age incl: >40; Mean age: 57.9 % Ethnicity: NR % Female: 25.4 % FH: 0 | Any polyps: 7.3% Any neoplasm: 28% Adv. neoplasm: 7% CRC: 0.5% | PA: NR APA: NR P-CRC: NR PAN: 2.5% (56/2110) | 1.3% (23/1836) | 4.2% (14/331) | 16% (19/119) | 85.3% (133/156) | NR | NR | NR
Ikeda 2000 ^145^ Japan Distal definition: splenic flexure, descending & sigmoid colon, rectum | N: 3,131 Age incl: 48–57; Mean age: 61.2 % Ethnicity: [Japanese] % Female: 0 % FH: NR | Any polyps: NR Any neoplasm: 25.9% Adv. neoplasm: 2.4% CRC: 0.6% | PA: 12% (376/3131) APA: NR P-CRC: 0.1% PAN: 0.9% (29/3131) | 0.8% (20/2620) | 1.3% (6/461) | 6.0% (3/50) | 73.7% (56/76) | NR | NR | NR
Anderson 2004 ^58^ USA Distal definition: descending & sigmoid colon, rectum | N: 1,988 Age incl: >40; Mean age: 57.2 % Ethnicity: 1.5 nonwhite % Female: 45.6 % FH: 13.6 | Any polyps: NR Any neoplasm: 21.9% Adv. neoplasm: 10.2% CRC: 0.4% | PA: NR APA: NR P-CRC: NR PAN: NR | 3.2% (55/1697) | NR | NR | 73.8% (155/210) | NR | 62.5% (5/8) | NR
Imperiale 2003 ^146^ Imperiale 2000 ^59^ USA Distal definition: descending & sigmoid colon, rectum | N: 3,025 (1994 subgroup) Age incl: ≥50; Mean age: 58.9 % Ethnicity: 90 white % Female: 42 % FH: NR | Any polyps: NR Any neoplasm: NR Adv. neoplasm: 6.0% CRC: NR | PA: NR APA: NR P-CRC: NR PAN: Male: 3.9% (68/1753) Female: 1.2% (15/1272) | Total: 1.8% Male: 2.5% (33/1309) Female: 0.84% (9/1075) | Total: 7.9% Male: 8.7% (14/161) Female: 5.9% (4/68) | Total: 12.5% Male: 14.3% (12/84) Female: 7.1% (2/28) | Total: 71.8% (130/181) Male: 70.0% (98/140) Female: 78.0% (32/41) | 76.8% (139/181) | 58.3% (7/12) | 75.0% (8/12)
Lieberman 2000 ^60^ USA Distal definition: descending & sigmoid colon, rectum | N: 3,121 Age incl: 50–75; Mean age: 62.9 % Ethnicity: 16.4 nonwhite % Female: 3.2 % FH: 13.9 | Any polyps: 53.8% Any neoplasm: 37.5% Adv. neoplasm: 10.5% CRC: 1.0% | PA: NR APA: NR P-CRC: NR PAN: 4.1% (128/3121) | 2.7% (48/1765) | 6.8% (38/561) | 11.4% (24/210) | 81.7% (272/333) | 85.6% (285/333) | NR | NR
Distal definition: sigmoid colon, rectum | 71.2% (237/333) | 78.7% (262/333) | NR | NR
Schoenfeld 2005 ^61^ USA Distal definition: descending & sigmoid colon, rectum | N: 1,463 Age incl: 40–79; Mean age: 58.9 % Ethnicity: 23 nonwhite % Female: 100 % FH: 15.7 | Any polyps: NR Any neoplasm: 20.4% Advanced neoplasm: 4.9% CRC: 0.1% | PA: NR APA: 3.4% (50/1462) P-CRC: NR PAN: 3.4% (50/1462) | 2.4% (36/1324) | 2.2% (3/138) | | 50% (36/72) | NR | NR | NR
Distal definition: sigmoid colon, rectum | 3.4% (47/1367) | 4.1% (3/73) | 0% (0/22) | 34.7% (25/72) | NR | NR | NR

Abbreviations: FH = family history; NR = not reported; CRC = colorectal cancer; PA = proximal adenoma; APA = advanced proximal adenoma; P-CRC = proximal invasive colorectal cancer; PAN = proximal adenomatous neoplasia

## KQ2A Miss rates of flexible sigmoidoscopy

Table 4 KQ2A Miss rates of flexible sigmoidoscopy

Study | Setting Targeted Population | Reference Standard Operator Characteristics | Inclusion / Exclusion Criteria | Patient Characteristics | Prevalence and Yield of Polyps | Miss Rates (Any polyp, Adenomas, high-risk adenomas, CRC) | | | Screening Test Adequacy | Comments
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | FS; applied to 100% of pts Nurse endoscopist: (2+ years as gastro nurse; 100+ supervised FS; 50 independent procedures Gastroenterologists: 1–4 years exp; 1000+ endoscopies; one colorectal surgeon > 4 yrs experience and > 200 endoscopic procedures Pts randomized to either gastroenterologist or nurse endoscopist for first exam | Inclusion: Attended clinic for screening FS within 5-month period Exclusion: Too much stool retained for FS; medical condition made back to back FS harmful; inappropriate referral for screening (64 refused 2nd FS) | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | Gastro: n=162 # pts with adenomas: 26 (16%) # pts with anatomic polyps: 70 (43%) # pts with multiple anatomic polyps: 55 (17%) Nurse: n=151 # pts w/ adenomas: 17 (11%) # pts w/ anatomic polyps: 68 (45%) # pts w/ multiple anatomic polyps: 33 (22%) All NS | Person Miss Rate: (Gastro; Nurse) pts w/ anatomic polyp: 51% (64/126); 47% (58/123) pts w/ polyp 1st FS: 40% (50/126); 41% (51/123) pts w/ polyp 2nd FS: 23% (29/126); 14% (17/123) pts w/ no polyp 1st FS found on 2nd FS: 12% (14/126); 6% (7/123) pts w/ no adenoma on 1st found on 2nd FS: 3% (4/126); 2% (2/123) All NS Adenoma miss rates: N: 249 | | | % refused 2nd exam: 20 | pg 316, if the sigmoidscope was only inserted 35 cm during 1st FS then descending colon polyps were frequently missed. The 1st FS inserted the scope at least 50 cm in (223/249) 90% of pts. In these pts only 3 additional polyps were found when the sigmoidscope was inserted further during the 2nd FS. Depth of FS was limited to 35 cm in (11/249) 4.4% of pts. Of these pts 27% had additional polyps
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | | Gastro (n: 126) [underlined: missed/total polyps] | Nurse (n: 123) [underlined: missed/total polyps] | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | 1–5 mm | 2/15 | 3/8 | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | 6–9 mm | 2/5 | 0/2 | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | ≥10 mm | 2/10 | 0/4 | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | Polyp miss rates: | | | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | | [underlined: Gastro] | [underlined: Nurse] | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | All polyps | 29% (41/139) | 17%(22/128); p=0.02 | % refused 2nd exam: 20
Schoenfeld 1999 ^141^ | Bethesda, MD: Hospital All pts attending for FS in 5-month period | | | N: 313 enrolled; 249 completed both FS Gastro (n: 162) Age: 61± 10 yr % Female: 33 Nurse (n: 151) Age: 59± 10 yr % Female: 34 All NS | | Hyperplastic | 32% (35/109) | 17% (19/114); p=0.01 | % refused 2nd exam: 20
Adenoma | 20% (6/30) | 21% (3/14); NS
Burke 2006 ^143^ | Cleveland Clinic Subjects chosen from a cohort of pts undergoing FS for CRC screening between 1987 and 2002, as those with an initial negative FS | Repeat FS 3–5 years later Staff gastroenterologists | Inclusion: Asymptomatic pts; No other concurrent method of screening; all examinations had adequate preparation; had a normal baseline FS; had a followup examination 3 yrs (+/-6 months) or 5 yrs (+/- 6 months) later. Only subjects with two FS examinations were included in the cohort. | N: 2,146 Age (mean): 54 yr % Female: 36 % Ethnicity: NR SES: NR % with Risk Factors: NR | N/A (initial exam negative) | 3.2% of 915 subjects had neoplasia detected on 3-yr follow-up FS. Of the total lesions, approximately 60% were tubular adenomas, and 40% were tubulovillous or more advanced. 1 carcinoma was found in 915 subjects at 3 yr follow-up. 93% of the neoplasms in the 3-yr subjects were in the area of the colorectum that had been previously examined | | | | Unclear what number of pts with an initial negative screening FS were lost to followup. Also not stated what proportion in cohort were excluded due to poor bowel preparation
Schoen 2003 ^142^ | PLCO trial, multicenter American screening study Sample taken from the (randomized) intervention arm of a large multicenter screening study. | Repeat FS, sometimes with colonoscopic re-examination 3 years later Trained nurses or certified physicians | Inclusion: Age 55–74 years; no current treatment for cancer except basal cell or squamous cell skin cancer; no known prior cancer of the colon, rectum, prostate, lung or ovaries; no surgical removal of the colon, lung, ovary or prostate; no participation in another cancer screening or cancer prevention trial; no finasteride use (in men) or no tamoxifen use (in women) in the past 6 months; provision of informed consent; no more than 1 prostate-specific antigen test in the past 3 years (for men randomized after April 1995); and no colonoscopy, sigmoidoscopy, or barium enema in the past 3 years (for individuals randomized after April 1995). | N: 9,317 Age (mean): 65.7 yr % Female: 38.4 % Ethnicity: White, NH: 86.7 Hispanic: 1.1 Black, NH: 3.8 Asian: 7.5 Other: 0.9 % SES: High school grad or less : 27 High school grad, less than college grad: 31.7 College grad: 19.5 Postgrad training: 21.8 % with risk factors: 10.1 reported a FH of CRC in a first degree relative | N/A (initial exam negative) | | Distal colon | Prox Colon | 9,317 of 11,583 indv. (80.4%) without a polypoid mass or lesion on initial FS returned for repeat screening 3 yr later. Of the 9,317 indv, 8,025 (86.1%) had nonsuspicious findings. Of the 1,292 with abnormal, suspicious findings, 951 (73.6%) had diagnostic followup (341 did not). Of the 951 with diagnostic followup, 847 had colonoscopy (89.1%) and 104 had FS (10.9%). | Only those with abnormal findings on FS had a followup colonoscopy
Schoen 2003 ^142^ | PLCO trial, multicenter American screening study Sample taken from the (randomized) intervention arm of a large multicenter screening study. | Repeat FS, sometimes with colonoscopic re-examination 3 years later Trained nurses or certified physicians | | | N/A (initial exam negative) | Nonadvanced adenoma | 214 | 124 | | Only those with abnormal findings on FS had a followup colonoscopy
Schoen 2003 ^142^ | PLCO trial, multicenter American screening study Sample taken from the (randomized) intervention arm of a large multicenter screening study. | Repeat FS, sometimes with colonoscopic re-examination 3 years later Trained nurses or certified physicians | | | N/A (initial exam negative) | Advanced adenoma | 72 | 39 | | Only those with abnormal findings on FS had a followup colonoscopy
Schoen 2003 ^142^ | PLCO trial, multicenter American screening study Sample taken from the (randomized) intervention arm of a large multicenter screening study. | Repeat FS, sometimes with colonoscopic re-examination 3 years later Trained nurses or certified physicians | | | N/A (initial exam negative) | Cancer | 6 | 1 | | Only those with abnormal findings on FS had a followup colonoscopy
Schoen 2003 ^142^ | PLCO trial, multicenter American screening study Sample taken from the (randomized) intervention arm of a large multicenter screening study. | Repeat FS, sometimes with colonoscopic re-examination 3 years later Trained nurses or certified physicians | | | N/A (initial exam negative) | Total | 292 | 164 | | Only those with abnormal findings on FS had a followup colonoscopy
Prevalence of distal advanced adenoma or cancer at 3 years followup is 78/9,317 = 0.8%Prevalence of proximal advanced adenoma or cancer at 3 years followup is 40/9,317 = 0.4% Prevalence of any distal adenoma or cancer at 3 years is 292/9,317 = 3.1%

## Missed and interval cancers estimated on follow-up colonoscopy or retrospectively from diagnosed CRC

Table 5 Missed and interval cancers estimated on follow-up colonoscopy or retrospectively from diagnosed CRC

Author, year | Cohort characteristics | Follow-up | Proportion with CRC on follow-up | Study limitations
Prospective studies of screening colonoscopy
Imperiale, 2008 ^331^ | 1,256 of 2,436 persons with a negative screening colonoscopy who had a repeat screening colonoscopy 5 years later | Repeat colonoscopy 5 years later | 0 of 1256 were diagnosed with CRC within the next 5 years | Low follow-up of original cohort, sensitivity analysis done for adenomas and advanced neoplasia, but not CRC Time interval of follow-up may not correspond to “missed” cancer Unclear generalizablity of endoscopists to community setting
Lieberman, 2007 ^332^ | 298 of 501 patients selected from a pool of 1,950 that had an initially negative screening colonoscopy and repeat colonoscopy in 5.5 years; - 23.8% of 298 patients had a family history of CRC | Repeat colonoscopy 5.5 years later | 1 of 298 was diagnosed with CRC within 5 years 1/298 = 0.3% interval incidence of CRC | Low follow-up of original cohort Time interval of follow-up may not correspond to “missed” cancer
Rex, 1996 ^333^ | 154 of 368 patients with a negative initial screening colonoscopy who had a repeat colonoscopy 5.5 years later | Repeat colonoscopy at a mean of 5.5 years later | 0 of 154 were diagnosed with CRC | Low follow-up of original cohort Time interval of follow-up may not correspond to “missed” cancer
Prospective studies of diagnostic colonoscopy
Hosokawa, 2003 ^334^ | List of 7,365 patients who had a colonoscopy (and no CRC found) during a 5 year period in a community hospital in Japan, who had:; - No adenomas or; - Adenomas without high-grade dysplasia; [underlined: Reasons for colonoscopy:] Surveillance: 32.7% +FOBT/DCBE: 30% Screening: 6.5% Signs/symptom disease: 13.2% IBD surveillance: 1.9% Other/not stated: 16% | Matched with entries on the local government-based Cancer registry at 3 yrs | 15 of those diagnosed with CRC during the next 3 years (248) had a negative colonoscopy 15 / 7,365 = 0.2% interval incidence of CRC | High proportion of initial cohort had colonoscopy for reasons other than screening No clear differentiation between those without any adenomas on colonoscopy and those with low-grade adenomas
Neugut, 1995 ^335^ | 99 of 508 patients who had an initially negative colonoscopy, and had a repeat colonoscopy within the next 3 years; - 59.6% symptomatic; - 37.4% had family history of CRC | A second colonoscopy within 3 years | 0 of 99 were diagnosed with CRC | High proportion of initial cohort had colonoscopy for reasons other than screening Low follow-up of original cohort
Avidan, 2002 ^336^ | 391 patients at the Hines VA Hospital, with negative screening colonoscopy followed by a second 1–5 years later.; - 44.8% had ≥ 1 first degree relatives with CRC.; - 98.5% male | Repeat colonoscopy 1–5 years later | 2 of 391 were diagnosed with CRC within the next 5 years 2 / 391 = 0.5% interval incidence of CRC | High proportion of patients with a family history of CRC Size of original cohort (those with a first colonoscopy only) not stated. Time interval of follow-up may not correspond to “missed” cancer
Retrospective studies of screening or diagnostic colonoscopy
Bressler, 2007 ^242^ | 12,487 patients with a diagnosis of CRC, 430 of whom had received a colonoscopy within 36 months prior to CRC diagnosis | Those with a screening colonoscopy 6–36 months prior to CRC diagnosis were defined as missed or interval CRC. | 430 / 12,487 =3.4% with a diagnosis of CRC had a ‘missed’ or ‘interval’ cancer | Unknown proportion of initial cohort had colonoscopy for reasons other than screening
Sawhney, 2006 ^337^ | 993 patients with a diagnosis of CRC, 51 had received a complete colonoscopy within 5 years prior to CRC diagnosis 98% Male | Those with a colonoscopy within 5 yrs of CRC diagnosis were defined as missed or interval cancer. | 51 / 993 = 5.1% with a diagnosis of CRC had a ‘missed’ or ‘interval’ cancer | Unknown proportion of initial cohort had colonoscopy for reasons other than screening Time interval of follow-up may not correspond to “missed” cancer
Rex, 1997 ^338^ | 941 patients with a diagnosis of CRC, 47 had received a complete colonoscopy within 3 years prior to CRC diagnosis; - 66 of 941 patients had colonoscopy for screening | Those with a colonoscopy within 3 yrs of CRC diagnosis were defined as missed or interval cancer. | 47 / 941 = 5.0% with a diagnosis of CRC had a ‘missed’ or ‘interval’ cancer | High proportion of initial cohort had colonoscopy for reasons other than screening
Farrar, 2006 ^339^ | 830 patients with a diagnosis of CRC, 45 had received a complete colonoscopy within 5 years prior to CRC diagnosis | Those with a colonoscopy within 5 yrs of CRC diagnosis were defined as missed or interval cancer. | 45 / 830 = 5.4% with a diagnosis of CRC had a ‘missed’ or ‘interval’ cancer | Time interval of follow-up may not correspond to “missed” cancer Unknown proportion of initial cohort had colonoscopy for reasons other than screening