# Appendix A. Detailed Methods

## Update Key Questions and Analytic Framework

Under the guidance of the USPSTF, we developed an analytic framework and five key questions (Figure 1), which received final approval from USPSTF liaisons. This report's scope differs from the 2002 USPSTF evidence report in several important ways:

1 We did not update the direct evidence that standard FOBT screening is effective, except in addressing longer-term follow-up results from the original trials included in the 2002 report, because this evidence was foundational for the last recommendation.
2 We did not update evidence on CRC screening methods not recommended after the last review (e.g., digital rectal exam) or omitted from this review by the USPSTF due to poor test performance characteristics (e.g., DCBE). A single study (n=580) from the previous 2002 evidence report found that DCBE as a surveillance method after adenomatous polypectomy (with comparison to colonoscopy as the gold standard) showed a sensitivity of only 48 percent (CI: 24, 67) for polyps larger than 10 mm. A more recent study in a high-risk screening and diagnostic evaluation population comparing DCBE to both optical and CT colonoscopy showed similarly low sensitivity estimates for large polyps. ^115^ Given its confirmed low sensitivity for the targets of screening (lesions 10 mm or larger), DCBE as a primary CRC screening test was removed from the review.
3 Systematic review of screening test adherence, acceptability, and feasibility was not part of this report. Similarly, the USPSTF judged that a thorough review of cost effectiveness analyses was beyond the scope of our review, particularly since the USPSTF was conducting a simultaneous decision analysis. This separate decision analysis also removed the systematic review of evidence on screening intervals and on ages to start and stop screening from our formal systematic review.

Figure 1. Literature retrieval process: Search results and article flow by Key Question*

KQ1 examined direct evidence that screening programs for colorectal cancer in primary care comparable patients reduce morbidity and/or mortality. KQ2A examined the effectiveness of colonoscopy and/or sigmoidoscopy in the community practice setting for CRC screening. KQ2B examined the efficacy of CT colonography and fecal screening tests including high-sensitivity guaiac FOBT, immunochemical FOBT, and fecal DNA tests for CRC screening. KQ3A examined the adverse effects of colonoscopy or sigmoidoscopy, in the community practice setting, used for CRC screening. KQ3B examined the adverse effects of CT colonography and fecal screening tests for CRC screening.

## Literature Search Strategy

We initially searched for synthesized literature and guidelines published since the previous USPSTF report in PubMed, Database of Abstracts of Reviews of Effectiveness (DARE), Health Technology Assessment Database (HTA), and the Cochrane Database of Systematic Reviews (CDSR). We also searched the National Guideline Clearinghouse, Institute of Medicine, and National Institute for Clinical Evidence websites for relevant reports.

For all key questions, we used already synthesized literature to the extent possible, supplementing with primary literature searches bridging from the search windows of relevant systematic reviews and meta-analyses. We developed literature search strategies and terms for each KQ (see Appendix A Table 1), with search dates guided by existing systematic reviews (including the 2002 UPSPTF report) and the development of screening technology.

We conducted five separate literature searches in both Medline and Cochrane Central Register of Controlled Trials (CCRCT). Search one was for KQ1, search two was for KQ2A, search three was for KQ2B, search four was for KQ3A and KQ3B, and search five was a more complex search of harms for KQ3A and KQ3B. Although the searches were specifically designed for a particular key question, all abstracts were reviewed for inclusion in all key questions. All searches went through January 2008.

For KQ1 (mortality outcomes of screening), we found no systematic reviews conforming to our inclusion and exclusion criteria more recent than the 2002 USPSTF review. Therefore, we searched for newly published primary literature from January, 2000 through January, 2008.

For KQ2a (accuracy of flexible sigmoidoscopy and colonoscopy), we found no systematic reviews conforming to our inclusion and exclusion criteria more recent than the 2002 USPSTF review and therefore searched from January, 2000 through January, 2008 for primary literature.

KQ2b (test performance characteristics of newer screening tests) covered three tests: CT colonography, fecal immunochemical tests (FIT), and fecal DNA tests. Three separate approaches were used for the three different tests. For CT colonography, a good-quality review published in 2005 ^116^ used acceptable methods and reported their methods and the data necessary for us to use as a foundation for further searching. This review was compared with five other recently published reviews of CT colonography (Hayes report (searched through Dec 2005)); ^117^ – ^121^ and we reviewed for inclusion any articles we found that were not reported in Mullhall et al's review. The most recent search date among the 6 reviews ^116^ – ^121^ was December 2005. Therefore we searched from January, 2006 through August, 2007 for primary literature.

Although we found several reviews of FIT, none clearly met our standards for methods and reporting and we therefore used these reviews only as sources of articles and conducted our own searches beginning in 1990, when the early primary literature was being published on FIT. A good-quality TEC assessment ^124^ was used as the basis for fecal DNA test literature, which searched through June, 2006. Using this review as our foundation, we search from January, 2006 through January, 2008.

For KQ3a and KQ3b (harms of screening tests) we found no synthesized evidence more recent than the 2002 USPSTF review that could be used as a foundation for the current review and therefore searched Medline and CCRCT from January, 2000 through January, 2008. We developed two different search strategies: one comprehensive, broad strategy that yielded many irrelevant abstracts, and one more focused strategy with fewer irrelevant abstracts. Although our pilot-testing of the more focused strategy suggested that it was sufficiently comprehensive, we nevertheless coded all the abstracts from the broader strategy for January 2006 – January 2008.

## Study Selection

Two investigators reviewed all 3948 abstracts and 488 full-text articles. Abstracts and articles were evaluated against a set of inclusion/exclusion criteria for each key question (see Appendix A Table 2) and required the agreement of 2 reviewers. Eligible studies reported on the performance of colorectal cancer screening tests (sensitivity and specificity) or health outcomes. We excluded studies that did not address average-risk populations for colorectal cancer screening, unless an average-risk subgroup was reported. Studies including persons with a family history of CRC were considered acceptable, unless the familial history included heritable syndromes such as FAP (Familial Adenomatous Polyposis), HNPCC (Hereditary Non-polyposis Colorectal Cancer, or Lynch Syndrome), Gardner syndrome (FPC, Familial Polyposis Coli), Turcot syndrome, and Peutz-Jeghers syndrome. Since the applicability of the diagnostic accuracy of screening tests in persons undergoing ‘surveillance’ is uncertain, we limited our inclusion to studies with surveillance populations of less than 50%. However, symptomatic persons, persons with iron deficiency anemia, and persons with positive FOBT, were not considered acceptable populations for extrapolation of diagnostic accuracy studies. Therefore, we limited our inclusion to studies with these populations to less than 10 percent. We excluded case—control studies of screening accuracy because these may overestimate sensitivity as a design-related source of bias, ^154^ as recently demonstrated for FOBTs. ^122^ To avoid biases related to reference standards, we excluded studies of test accuracy that incompletely applied a valid reference standard or used an inadequate reference standard. ^328^ For CT colonography, we considered only technologies that were compared against colonoscopy in average-risk populations, used a multidetector scanner, ^116^ and reported per-patient sensitivity and specificity.

## Quality Assessment and Data Abstraction

Two investigators critically appraised and quality-rated all eligible studies by using design-specific quality criteria based on the USPSTF methods (Appendix A Table 3), supplemented by NICE and Oxman criteria for systematic reviews, ^127,^ ^128^ and QUADAS criteria for diagnostic accuracy studies. ^329^ Only good-quality systematic reviews were used as sources for primary articles, and all poor-quality studies were excluded from the review. One investigator abstracted key elements of all included studies into standardized evidence tables. A second reviewer verified these data. Disagreements about data abstraction or quality appraisal were resolved by consensus.

## Literature Synthesis

No studies were found for KQ1 and therefore no data synthesis was required. Results of KQ2b and KQ3b were judged to be too heterogeneous in terms of populations, settings, and study designs for meta-analysis and were therefore qualitatively synthesized.

Although we had some concerns about the level of heterogeneity in the populations of the KQ2a studies, we nevertheless explored the statistical heterogeneity of the KQ2a studies for adenoma miss rates and polyp miss rates using Stata v9.2 “meta” command. Not surprisingly, Q statistics indicated significant statistical heterogeneity as well (Q=22.6, p<.001 for adenoma miss rates, Q=37.8, p<.001 for polyp miss rates) and meta-analysis results are not presented for KQ2a. Data were too limited to explore heterogeneity through statistical means.

Due to study design and limitations in reporting for two of the studies evaluating CTC test performance, we calculated point estimates for per person sensitivity and specificity and their respective confidence intervals. The major limitation in calculating point estimates in these two studies, which evaluated the test performance of CTC between different radiologists using both 2D and 3D technology, is the double counting of lesions as independent, even though the radiologists were reading the same set of lesions (e.g., three radiologists reading three separate exams are pooled as if it was one radiologist reading nine exams). However, despite this limitation, the calculated point estimates and confidence intervals were not different from the range of estimates per reader presented in the original articles. We used the following formula to calculate confidence intervals (for p= proportion):

Because of the stringency of our inclusion criteria for key question 3a, which focused on estimates of harms in the community practice setting, the studies we included were thought to be clinically homogenous enough to allow pooling of complication rates. Meta-analysis was performed for KQ3a to estimate combined complication rates for serious bleeding, perforation, and any serious complications related to colonoscopy, and for any serious complications related to sigmoidoscopy. Several studies reported that their patients experienced no adverse events, and therefore we used a logistic random effects model ^129,^ ^130^ to include studies without any adverse events and estimate the combined complication rates. The model was described briefly as follows.

Suppose that there are i = 1, ..., n studies and number of complications and total procedures are x _i_ and n _i_ for study i. Denote that the complication rate from each study is p_i_, then we have

where μ_i_ is the random effects across studies and τ ^2^ estimates the heterogeneity among studies on the logit scale. The combined complication rate, p_com_, would be estimated by

This model allows inclusion of studies with no adverse events and the random effects incorporates variation among studies into the combined estimate. A p-value less than 0.05 for τ ^2^ is considered as statistically significant for heterogeneity.

Exploratory meta-regressions were conducted using logistic random effects models to examine the association of important study level characteristics: study design, study setting by country, and population characteristics including age range, and indication for endoscopy with complication rate. To do this, we only need to add one more term to equation (2) of the logistic random effects model:

where z_i_ represents any study level characteristics from study i and the association of this study characteristic with complication rate is investigated through β _1_.

The analysis was performed using the NLMIXED procedure in SAS v9.1 (see below for SAS code).

SAS Code for the Meta-Analysis of Serious Complications. The following SAS code shows how to calculate the combined rate of total serious complications and examines the impact of Community_setting (1 = Yes, 0 = No) on total serious complication rate using a logistic random-effects model with PROC NLMIXED.

data totalSC;
input Study$ | n_proc | n_serious_tot | Community_setting;
/* Community_setting = 1 if the study was conducted in a community setting;
0, otherwise */
datalines;

Kewenter_1996 | 190 | 3 | 0
Robinson_1999 | 1474 | 7 | 1
Thiis_1999 | 521 | 1 | 0
Nelson_2002 | 3196 | 18 | 0
Segnan_2002 | 775 | 2 | 0
Pickhardt_2003 | 1233 | 1 | 0
Cotterill_2005 | 324 | 0 | 1
Ko_2006 | 502 | 8 | 0
Levin_2006 | 16318 | 44 | 1
Rathgaber_2006 | 12407 | 14 | 1
ko_2007 | 18271 | 45 | 1

;

/** To obtain a combined rate of total serious complication rate */

proc nlmixed data = totalSC;

parms beta0 = -7.0 s2u = 0.5; /* Specify the initial value */

eta = beta0 + u;

/* Specify the model on logit scale where

beta0 will be used to estimate combined complication rate, and

u is the random-effects term across studies */

expeta = exp(eta);

p = expeta/(1+expeta);

model n_serious_tot ~ binomial(n_proc,p);

/* Specify the distribution for the number of complications */

random u ~ normal(0,s2u) subject=study;

/* Specify the distribution of random effects */

estimate “Complication Rate” exp(beta0)/(1+exp(beta0));

/* Obtain the combined complication rate using beta0 */

run;

/** To examine the impact of community setting on the total serious complication rate */

proc nlmixed data = totalSC;

parms beta0 = -7.0 s2u = 0.5 beta1 = 0.5; /* Specify the initial values */

eta = beta0 + beta1 * Community_setting + u;

/* Impact of community setting is investigated by beta1*/

expeta = exp(eta);

p = expeta/(1+expeta);

model n_serious_tot ~ binomial(n_proc,p);

/* Specify the distribution for the number of complications */

random u ~ normal(0,s2u) subject=study;

/* Specify the distribution of random effects */

run;

## External review process

The USPSTF appointed four liaisons to guide the scope and reporting of this review. The work plan was not reviewed by outside experts. A draft of the evidence synthesis was reviewed by eight experts, including experts in the fields of gastroenterology and radiology, and several experts who have written systematic evidence reviews on one or more aspects of colorectal cancer screening.

## USPSTF Involvement

The authors worked with four USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework questions and resolve issues around scope, and final evidence synthesis. Research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in external review of the draft evidence synthesis.

## Table 1. Search strategies

### Systematic Evidence Review Search

PubMed, DARE, Cochrane Database, IOM, HTA search to identify systematic reviews

#41 Search #22 OR #40

#40 Search #38 AND systematic[sb] Limits: English, Publication Date from 1999 to 2007

#39 Search #38 AND systematic[sb]

#38 Search #37 AND (publisher[sb] OR in process[sb])

#37 Search #33 OR #34 OR #35 OR #36

#36 Search sigmoidoscop*[tiab]

#35 Search colonograph*[tiab]

#34 Search colonoscop*[tiab]

#33 Search #32 AND screen*[tiab]

#32 Search #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31

#31 Search “colonic cancer”[tiab]

#30 Search “colonic neoplasms”[tiab]

#29 Search “colonic neoplasia”[tiab]

#28 Search “colon neoplasia”[tiab] 1

#27 Search “colorectal neoplasia”[tiab]

#26 Search “colon neoplasms”[tiab] 1

#25 Search “colorectal neoplasms”[tiab]

#24 Search “colon cancer”[tiab]

#23 Search “colorectal cancer”[tiab]

#22 Search #20 AND systematic[sb] Limits: English, Publication Date from 1999 to 2007

#21 Search #20 AND systematic[sb]

#20 Search #14 OR #19

#19 Search “Colonoscopy”[MeSH:NoExp] OR “Sigmoidoscopy”[MeSH] OR “Colonography, Computed Tomographic”[MeSH]

#14 Search #11 AND #13

#13 Search “Mass Screening”[MeSH:NoExp] OR screen*[tiab]

#11 Search #1 OR #6 OR #10

#10 Search “Intestinal Polyps”[MeSH:NoExp] OR “Colonic Polyps”[MeSH]

#6 Search “Rectal Neoplasms”[MeSH:NoExp] OR “Anus Neoplasms”[MeSH:NoExp] OR “Anal Gland Neoplasms”[MeSH]

#1 Search “Colorectal Neoplasms”[MeSH:NoExp] OR “Colonic Neoplasms”[MeSH:NoExp] OR “Sigmoid Neoplasms”[MeSH]

### Key Questions 1

Database: Ovid MEDLINE(R) <1966 to January 2008>

Search Strategy:

--------------------------------------------------------------------------------

1 Colonoscopy/
2 colonoscop$.ti,ab.
3 Sigmoidoscopy/
4 sigmoidoscop$.ti,ab.
5 Colonography, Computed Tomographic/
6 colonograph$.ti,ab.
7 Occult Blood/
8 fobt$.ti,ab.
9 ifobt$.ti,ab.
10 fecal occult blood.ti,ab.
11 faecal occult blood.ti,ab.
12 ((fecal or faecal) and immunochemical).ti,ab.
13 ((fecal or faecal) and dna).ti,ab.
14 instant-view.ti,ab.
15 immoCARE.ti,ab.
16 FlexSure OBT.ti,ab.
17 HemeSelect.ti,ab.
18 MonoHaem.ti,ab.
19 Hemoccult.ti,ab.
20 ColoScreen.ti,ab.
21 Seracult.ti,ab.
22 HM-Jack.ti,ab.
23 OcculTech.ti,ab.
24 PreGen-Plus.ti,ab.
25 QuickVue.ti,ab.
26 HemoQuant.ti,ab.
27 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26
28 Mass Screening/
29 screen$.ti,ab.
30 28 or 29
31 27 and 30
32 limit 31 to (clinical trial or controlled clinical trial or randomized controlled trial)
33 clinical trials/ or controlled clinical trials/ or randomized controlled trials/
34 double-blind method/ or random allocation/ or single-blind method/
35 random$.ti,ab.
36 33 or 34 or 35
37 31 and 36
38 Colorectal Neoplasms/
39 Colonic Neoplasms/
40 Sigmoid Neoplasms/
41 Rectal Neoplasms/
42 Anus Neoplasms/
43 Anal Gland Neoplasms/
44 Intestinal Polyps/
45 Colonic Polyps/
46 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45
47 46 and 28
48 46 and screen$.ti.
49 47 or 48
50 limit 49 to (clinical trial or controlled clinical trial or randomized controlled trial)
51 49 and 36
52 Mortality/
53 mortality.fs.
54 Survival Rate/
55 survival analysis/
56 Life Expectancy/
57 “Cause of Death”/
58 mortality.ti,ab.
59 death.ti,ab.
60 deaths.ti,ab.
61 survival.ti,ab.
62 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61
63 31 or 49
64 62 and 63
65 32 or 37 or 50 or 51 or 64
66 limit 65 to humans [Limit not valid; records were retained]
67 limit 65 to animals
68 67 not 66
69 65 not 68
70 limit 69 to english language
71 limit 70 to yr=“2000 - 2008”

Database: EBM Review : Cochrane Central Registries of Controlled Trials <1985 to 4^th^ quarter 2007>

Search Strategy:

--------------------------------------------------------------------------------

1 colonoscop$.ti,ab,hw. (789)
2 sigmoidoscop$.ti,ab,hw. (362)
3 colonograph$.ti,ab,hw. (26)
4 occult blood.hw. (260)
5 fecal occult blood.ti,ab. (97)
6 faecal occult blood.ti,ab. (75)
7 ((fecal or faecal) and immunochemical).ti,ab. (9)
8 ((fecal or faecal) and dna).ti,ab. (15)
9 (fobt$ or ifobt$).ti,ab. (38)
10 (instant-view or immoCARE or FlexSure OBT).ti,ab. (4)
11 (HemeSelect or MonoHaem or Hemoccult).ti,ab. (63)
12 (ColoScreen or Seracult or HM-Jack or OcculTech or PreGen-Plus).ti,ab. (2)
13 (quickvue or hemoquant).ti,ab. (10)
14 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 (1322)
15 screening.hw. (2409)
16 screen$.ti,ab. (7222)
17 15 or 16 (8051)
18 14 and 17 (300)
19 (colon$ and (cancer or neoplas$)).hw. (1679)
20 (colorectal and (cancer or neoplas$)).hw. (1416)
21 (rectal and (cancer or neoplas$)).hw. (806)
22 (colon$ and (cancer or neoplas$)).ti. (476)
23 (colorectal and (cancer or neoplas$)).ti. (1285)
24 (rectal and (cancer or neoplas$)).ti. (322)
25 19 or 20 or 21 or 22 or 23 or 24 (3896)
26 25 and 15 (232)
27 25 and screen$.ti. (236)
28 18 or 26 or 27 (371)
29 limit 28 to yr=“2000- 2008” (158)

### Key Question 2A

Database: Ovid MEDLINE(R) <1996 to January 2008>

Search Strategy: Part 1

--------------------------------------------------------------------------------

1 Sigmoidoscopy/
2 Colonoscopy/
3 1 or 2
4 “Sensitivity and Specificity”/
5 “Predictive Value of Tests”/
6 ROC Curve/
7 False Negative Reactions/
8 False Positive Reactions/
9 Diagnostic Errors/
10 “Reproducibility of Results”/
11 Reference Values/
12 Reference Standards/
13 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14 3 and 13
15 Colonoscopy/st [Standards]
16 Sigmoidoscopy/st [Standards]
17 14 or 15 or 16
18 limit 17 to english language
19 limit 18 to yr=“2000 - 2008”
20 colonoscop$.ti,ab.
21 sigmoidoscop$.ti,ab.
22 1 or 2 or 20 or 21
23 specificit$.ti,ab.
24 sensitiv$.ti,ab.
25 predictive value.ti,ab.
26 accurac$.ti,ab.
27 miss rate$.ti,ab.
28 detection rate$.ti,ab.
29 diagnostic yield$.ti,ab.
30 likelihood ratio$.ti,ab.
31 diagnostic odds ratio$.ti,ab.
32 odds ratio/ and di.fs.
33 13 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34 22 and 33
35 15 or 16 or 34
36 limit 35 to english language
37 limit 36 to yr=“2000 - 2008”
38 Mass Screening/
39 screen$.ti,ab.
40 38 or 39
41 37 and 40
42 200608$.ed.
43 200608$.up.
44 42 or 43
45 41 and 44
46 19 not 41
47 45 or 46

Database: Ovid MEDLINE(R) <1996 to January 2008>

Search Strategy: Part 2

-------------------------------------------------------------------------

1 Sigmoidoscopy/
2 Colonoscopy/
3 1 or 2
4 “Sensitivity and Specificity”/
5 “Predictive Value of Tests”/
6 ROC Curve/
7 False Negative Reactions/
8 False Positive Reactions/
9 Diagnostic Errors/
10 “Reproducibility of Results”/
11 Reference Values/
12 Reference Standards/
13 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14 3 and 13
15 Colonoscopy/st [Standards]
16 Sigmoidoscopy/st [Standards]
17 14 or 15 or 16
18 limit 17 to english language
19 limit 18 to yr=“2000 - 2008”
20 colonoscop$.ti,ab.
21 sigmoidoscop$.ti,ab.
22 1 or 2 or 20 or 21
23 specificit$.ti,ab.
24 sensitiv$.ti,ab.
25 predictive value.ti,ab.
26 accurac$.ti,ab.
27 miss rate$.ti,ab.
28 detection rate$.ti,ab.
29 diagnostic yield$.ti,ab.
30 likelihood ratio$.ti,ab.
31 diagnostic odds ratio$.ti,ab.
32 odds ratio/ and di.fs.
33 13 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32
34 22 and 33
35 15 or 16 or 34
36 limit 35 to english language
37 limit 36 to yr=“2000 - 2006”
38 Mass Screening/
39 screen$.ti,ab.
40 38 or 39
41 37 and 40

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <4^th^ quarter 2007>

Search Strategy:

1 colonoscop$.hw.
2 sigmoidoscop$.hw.
3 1 or 2
4 sensitivity.hw.
5 specificity.hw.
6 predictive value.hw.
7 (roc or receiver operat$).hw.
8 false negative.hw.
9 false positive.hw.
10 diagnostic error$.hw.
11 reproducibility.hw.
12 reference value$.hw.
13 reference standards.hw.
14 diagnostic accuracy.hw.
15 diagnostic value.hw.
16 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15
17 3 and 16
18 colonoscop$.ti,ab.
19 sigmoidoscop$.ti,ab.
20 1 or 2 or 18 or 19
21 specificit$.ti,ab.
22 sensitiv$.ti,ab.
23 predictive value.ti,ab.
24 accurac$.ti,ab.
25 miss rate$.ti,ab.
26 detection rate$.ti,ab.
27 diagnostic yield$.ti,ab.
28 likelihood ratio$.ti,ab.
29 diagnostic odds ratio$.ti,ab.
30 (odds ratio and diagnosis).hw.
31 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30
32 20 and 31
33 screening.hw.
34 screen$.ti,ab.
35 33 or 34
36 32 and 35
37 17 or 36
38 limit 37 to yr=“2000 - 2008”

### Key Question 2B

Database: Ovid MEDLINE(R) <1950 to January 2008>

-----------------------------------------------------------------------

1 Colonography, Computed Tomographic/
2 colonograph$.ti,ab.
3 occult blood.ti,ab,hw.
4 guaiac.ti,ab,hw.
5 fobt$.ti,ab,hw.
6 fecal.ti,ab,hw.
7 faecal.ti,ab,hw.
8 feces.ti,ab,hw.
9 3 or 4 or 5 or 6 or 7 or 8
10 dna.ti,ab,hw.
11 9 and 10
12 pregen plus.ti,ab.
13 1 or 2 or 11 or 12
14 limit 13 to yr=“2006 - 2008”
15 ifobt.ti,ab.
16 i fobt.ti,ab.
17 instant-view.ti,ab.
18 immocare.ti,ab.
19 flexsure obt.ti,ab.
20 hemeselect.ti,ab.
21 monohaem.ti,ab.
22 hemosure.ti,ab.
23 hemoccult ict.ti,ab.
24 hm-jack.ti,ab.
25 occultech.ti,ab.
26 quickvue.ti,ab.
27 hemoquant.ti,ab.
28 immunochemi$.ti,ab,hw.
29 9 and 28
30 insure.ti,ab.
31 9 and 30
32 hemoccult sensa.ti,ab.
33 hemoccultsensa.ti,ab.
34 coloscreen es.ti,ab.
35 coloscreenes.ti,ab.
36 seracult plus.ti,ab.
37 seracultplus.ti,ab.
38 3 or 4 or 5
39 high sensitivity.ti,ab.
40 38 and 39
41 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 29 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 40
42 limit 41 to yr=“1990 - 2008”
43 “Sensitivity and Specificity”/
44 “Predictive Value of Tests”/
45 ROC Curve/
46 False Negative Reactions/
47 False Positive Reactions/
48 Diagnostic Errors/
49 “Reproducibility of Results”/
50 Reference Values/
51 Reference Standards/
52 Observer Variation/
53 Quality Control/
54 Quality Assurance, Health Care/
55 standards.fs.
56 specificit$.ti,ab.
57 sensitiv$.ti,ab.
58 predictive value.ti,ab.
59 accurac$.ti,ab.
60 false positive$.ti,ab.
61 false negative$.ti,ab.
62 miss rate$.ti,ab.
63 error rate$.ti,ab.
64 detection rate$.ti,ab.
65 diagnostic yield$.ti,ab.
66 likelihood ratio$.ti,ab.
67 odds ratio/ and di.fs.
68 diagnostic odds ratio$.ti,ab.
69 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65 or 66 or 67 or 68
70 14 or 42
71 69 and 70
72 limit 71 to english language
73 remove duplicates from 72

### Key Question 3A & 3B

Database: Ovid MEDLINE(R) <1996 to January 2008>

Search Strategy: Harms Simple

1 Colonoscopy/ae [Adverse Effects]
2 Colonoscopy/mo [Mortality]
3 Sigmoidoscopy/ae [Adverse Effects]
4 Sigmoidoscopy/mo
5 Colonography, Computed Tomographic/ae [Adverse Effects]
6 Colonography, Computed Tomographic/mo [Mortality]
7 virtual colonoscop$.ti,ab.
8 CT colonograph$.ti,ab.
9 computed tomographic colonograph$.ti,ab.
10 7 or 8 or 9
11 limit 10 to yr=“2000 - 2001”
12 (adverse effects or mortality).fs.
13 11 and 12
14 colonoscop$.ti.
15 sigmoidoscop$.ti.
16 colonograph$.ti.
17 14 or 15 or 16
18 complication$.ti.
19 adverse$.ti.
20 harm$.ti.
21 18 or 19 or 20
22 17 and 21
23 1 or 2 or 3 or 4 or 5 or 6 or 13 or 22
24 limit 23 to english language
25 limit 24 to humans
26 limit 24 to animals
27 26 not 25
28 24 not 27
29 limit 28 to yr=“2000 - 2008”

Database: Ovid MEDLINE(R) <1996 to January 2008>

Search Strategy: Harms Complex

---------------------------------------------------------------------------

1 colonoscopy/
2 colonoscop$.ti.
3 sigmoidoscopy/
4 sigmoidoscop$.ti.
5 polypectom$.ti.
6 Colonic Polyps/su [Surgery]
7 Intestinal Polyps/su [Surgery]
8 Adenomatous Polyps/su [Surgery]
9 Colonography, Computed Tomographic/
10 colonograph$.ti.
11 (colon cancer and screening).ti,ab.
12 (colorectal cancer and screening).ti,ab.
13 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14 harm.ti,ab.
15 harms.ti,ab.
16 harmed.ti,ab.
17 harmful$.ti,ab.
18 adverse effects.fs.
19 complication$.ti,ab.
20 side effect$.ti,ab.
21 adverse effect$.ti,ab.
22 adverse event$.ti,ab.
23 adverse reaction$.ti,ab.
24 death/
25 death$.ti,ab.
26 mortality.fs.
27 mortalit$.ti,ab.
28 or/14–27
29 13 and 28
30 pain/
31 pain.ti,ab.
32 painful.ti,ab.
33 discomfort.ti,ab.
34 cramps.ti,ab.
35 bloating.ti,ab.
36 chills.ti,ab.
37 dizziness.ti,ab.
38 weakness.ti,ab.
39 nausea/
40 nausea$.ti,ab.
41 vomiting/
42 vomiting.ti,ab.
43 bleeding.ti,ab.
44 Hemorrhage/
45 Gastrointestinal Hemorrhage/
46 Postoperative Hemorrhage/
47 hemorrhag$.ti,ab.
48 haemorrhag$.ti,ab.
49 perforat$.ti,ab.
50 Intestinal Perforation/
51 Intraoperative Complications/
52 Postoperative Complications/
53 or/30–52
54 13 and 53
55 ((anesthe$ or anaesthe$) and react$).ti,ab.
56 (coloring agents/ or tattoo$.ti,ab. or dye.ti,ab.) and react$.ti,ab.
57 Water-Electrolyte Imbalance/
58 electrolyte imbalance$.ti,ab.
59 electrolyte disturbance$.ti,ab.
60 Electrolyte disorder$.ti,ab.
61 electrolyte level$.ti,ab.
62 electrolyte abnormalit$.ti,ab.
63 Dehydration/
64 dehydrat$.ti,ab.
65 Hyponatremia/
66 Hyponatremia.ti,ab.
67 Hyponatraemia.ti,ab.
68 chemical colitis.ti,ab.
69 Colitis/ci [Chemically Induced]
70 or/55–69
71 13 and 70
72 emergency room.ti,ab.
73 emergency department.ti,ab.
74 Emergency Service, Hospital/
75 emergencies/
76 Hospitalization/
77 hospitaliz$.ti,ab.
78 hospitalise$.ti,ab.
79 hospitalisa$.ti,ab.
80 hospital admission$.ti,ab.
81 or/72–80
82 13 and 81
83 false positive$.ti,ab.
84 false negative$.ti,ab.
85 False Negative Reactions/
86 False Positive Reactions/
87 Diagnostic Errors/
88 overdiagnos$.ti,ab.
89 or/83–88
90 13 and 89
91 tolerability.ti,ab.
92 tolerable.ti,ab.
93 tolerate$.ti,ab.
94 tolerance.ti,ab.
95 intolera$.ti,ab.
96 Patient Acceptance of Health Care/
97 acceptance.ti,ab.
98 acceptability.ti,ab.
99 Patient Satisfaction/
100 Patient Compliance/
101 incomplete.ti,ab.
102 completion rate$.ti,ab.
103 failure rate$.ti,ab.
104 or/91–103
105 13 and 104
106 29 or 54 or 71 or 82 or 90 or 105
107 limit 106 to english language
108 limit 107 to humans
109 limit 107 to animals
110 109 not 108
111 107 not 110
112 Occult Blood/
113 fobt$.ti,ab.
114 ifobt$.ti,ab.
115 fecal occult blood.ti,ab.
116 faecal occult blood.ti,ab.
117 ((fecal or faecal) and immunochemical).ti,ab.
118 ((fecal or faecal) and dna).ti,ab.
119 hemoccult.ti,ab.
120 stool screening.ti,ab.
121 stool test$.ti,ab.
122 stool based test$.ti,ab.
123 Feces/
124 120 or 121 or 122 or 123
125 colorectal neoplasms/
126 colonic neoplasms/
127 sigmoid neoplasms/
128 rectal neoplasms/
129 anus neoplasms/
130 anal gland neoplasms/
131 Adenomatous Polyps/
132 intestinal polyps/
133 colonic polyps/
134 colorectal cancer.ti,ab.
135 colorectal neoplas$.ti,ab.
136 colon cancer.ti,ab.
137 colon neoplas$.ti,ab.
138 or/125–137
139 124 and 138
140 or/112–119
141 139 or 140
142 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 89 or 104
143 141 and 142
144 limit 143 to english language
145 limit 144 to humans
146 limit 144 to animals
147 146 not 145
148 144 not 147
149 111 or 148
150 limit 149 to yr=“2000 - 2007”
151 Colonoscopy/ae [Adverse Effects]
152 Colonoscopy/mo [Mortality]
153 Sigmoidoscopy/ae [Adverse Effects]
154 Sigmoidoscopy/mo
155 Colonography, Computed Tomographic/ae [Adverse Effects]
156 Colonography, Computed Tomographic/mo [Mortality]
157 virtual colonoscop$.ti,ab.
158 CT colonograph$.ti,ab.
159 computed tomographic colonograph$.ti,ab.
160 157 or 158 or 159
161 limit 160 to yr=“2000 - 2001”
162 (adverse effects or mortality).fs.
163 161 and 162
164 colonoscop$.ti.
165 sigmoidoscop$.ti.
166 colonograph$.ti.
167 164 or 165 or 166
168 complication$.ti.
169 adverse$.ti.
170 harm$.ti.
171 168 or 169 or 170
172 167 and 171
173 151 or 152 or 153 or 154 or 155 or 156 or 163 or 172
174 limit 173 to english language
175 limit 174 to humans
176 limit 174 to animals
177 176 not 175
178 174 not 177
179 limit 178 to yr=“2000 - 2008”
180 150 not 179
181 limit 180 to yr=“2006 - 2008”

Database: EBM Reviews Cochrane Central Registry of Controlled Trials <4^th^ quarter 2007>

Search Strategy:

---------------------------------------------------------------------------

1 colonoscop$.ti,hw.
2 sigmoidoscop$.ti,hw.
3 colonograph$.ti,hw.
4 1 or 2 or 3 (899)
5 complication$.ti,hw.
6 adverse$.ti,hw.
7 harm$.ti,hw.
8 mortalit$.ti,hw.
9 side effect.ti,hw.
10 5 or 6 or 7 or 8 or 9
11 4 and 10
12 limit 11 to yr=“2000 - 2007”

Table 2 Inclusion/Exclusion Criteria

Key Question | Population | Study Design | Setting | Outcomes | Other
KQ 1 Impact of screening on mortality | Age ≥ 40 y; average risk Recruited from primary care or primary care—comparable population | Systematic evidence review; RCT; cluster RCT; or well-designed CCT, cohort, and case—control studies | Primary care or other setting with primary care—comparable population | Mortality (all-cause or CRC-specific) | For guaiac FOBT, only updates for the trials included in the previous review were considered.
KQ 2a Accuracy of flexible sigmoidoscopy and colonoscopy (community setting) | Age ≥ 40 y; average risk Recruited from primary care or primary care—comparable population | Systematic evidence review; RCT; cohort studies; systematically selected case series; screening registry | Community primary care or other setting with primary care—comparable population | Sensitivity and specificity (per person) or miss rates (per polyp); yield for CRC, advanced neoplasia, or adenomas by size | Colonoscopy as reference standard; full spectrum of disease represented; indeterminate results not excluded
KQ 2b Accuracy of newer screening tests (CTC, high-sensitivity FOBT, FIT, fecal DNA) | Age ≥ 40 y; average risk Recruited from primary care or primary care—comparable population | Systematic evidence review; RCT; diagnostic cohort studies; systematically selected case series; screening registry | Any | Sensitivity and specificity (per person) or miss rates (per polyp); yield for CRC, advanced neoplasia, or adenomas by size | Colonoscopy (or registry follow-up) as reference standard; full spectrum of disease represented; indeterminate results not excluded
KQ 3a Harms of flexible sigmoidoscopy and colonoscopy (community setting) | Age ≥ 40 y; average risk Recruited from primary care or primary care—comparable population | Systematic evidence review; RCT/CCT; registries; large-database observational studies, cohort studies; cross-sectional studies; systematically selected case series | Community primary care or other setting with primary care—comparable population | Adverse events requiring hospitalization, including perforation, major bleeding, severe abdominal symptoms, cardiovascular events, and/or resulting in death | Harms due to bowel preparation and sedation considered separate from serious adverse events
KQ 3b Harms of newer screening tests (CTC, high-sensitivity FOBT, FIT, fecal DNA) | Age ≥ 40 y; average risk | Systematic evidence review; RCT/CCT; registries; large-database observational studies, cohort studies; cross-sectional studies; systematically selected case series | Any | Adverse events requiring hospitalization, including perforation, major bleeding, severe abdominal symptoms, cardiovascular events, and/or resulting in death | Potential harms due to radiation and extracolonic findings considered separate from serious adverse events

* CCT = controlled clinical trial; CRC = colorectal cancer; CT = computed tomography; FIT = fecal immunochemical test; FOBT = fecal occult blood test; KQ = key question; RCT = randomized, controlled trial.

Table 3 Quality rating criteria

Design | United States Preventive Services Task Force quality rating criteria ^114^ | National Institute for Health and Clinical Excellence methodology checklists
Systematic reviews and meta-analyses | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance are especially important for systematic reviews | - The study addresses an appropriate and clearly focused question; - A description of the methodology used is included; - The literature search is sufficiently rigorous to identify all the relevant studies; - Study quality is assessed and taken into account; - There are enough similarities between the studies selected to make combining them reasonable
Case-control studies | - Accurate ascertainment of cases; - Nonbiased selection of cases/controls with exclusion criteria applied equally to both; - Response rate; - Diagnostic testing procedures applied equally to each group; - Measurement of exposure accurate and applied equally to each group; - Appropriate attention to potential confounding variables | - The study addresses an appropriate and clearly focused question; - The cases and controls are taken from comparable populations; - The same exclusion criteria are used for both cases and controls; - What percentage of each group (cases and controls) participated in the study?; - Comparison is made between participants and non-participants to establish their similarities or differences; - Cases are clearly defined and differentiated from controls; - Is it clearly established that controls are non-cases?; - Measures have been taken to prevent knowledge of primary exposure influencing case ascertainment; - Exposure status is measured in a standard, valid and reliable way; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided?
Randomized controlled trials (RCTs) | - Initial assembly of comparable groups employs adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The assignment of subjects to treatment groups is randomized; - An adequate concealment method is used; - Subjects and investigators are kept ‘blind’ about treatment allocation; - The treatment and control groups are similar at the start of the trial; - The only difference between groups is the treatment under investigation; - All relevant outcomes are measured in a standard, valid and reliable way; - What percentage of the individuals or clusters recruited into each treatment arm of the study dropped out before the study was completed?; - All the subjects are analyzed in the groups to which they were randomly allocated (often referred to as intention-to-treat analysis); - Where the study is carried out at more than one site, results are comparable for all sites
Cohort studies | - Initial assembly of comparable groups employs consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination); - Important differential loss to follow-up or overall high loss to follow-up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of the interventions; - All important outcomes considered | - The study addresses an appropriate and clearly focused question; - The two groups being studied are selected from source populations that are comparable in all respects other than the factor under investigation; - The study indicates how many of the people asked to take part did so, in each of the groups being studied; - The likelihood that some eligible subjects might have the outcome at the time of enrollment is assessed and taken into account in the analysis; - What percentage of individuals or clusters recruited into each arm of the study dropped out before the study was completed?; - Comparison is made between full participants and those lost to follow-up, by exposure status; - The outcomes are clearly defined; - The assessment of outcome is made blind to exposure status; - Where blinding was not possible, there is some recognition that knowledge of exposure status could have influenced the assessment of outcome; - The measure of assessment of exposure is reliable; - Evidence from other sources is used to demonstrate that the method of outcome assessment is valid and reliable; - Exposure level or prognostic factor is assessed more than once; - The main potential confounders are identified and taken into account in the design and analysis; - Have confidence intervals been provided?
Diagnostic accuracy studies | - Screening test relevant, available for primary care, adequately described; - Study uses a credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Handles indeterminate result in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Administration of reliable screening test | - The nature of the test being studied is clearly specified; - The test is compared with an appropriate gold standard; - Where no gold standard exists, a validated reference standard is used as a comparator; - Patients for testing are selected either as a consecutive series or randomly, from a clearly defined study population; - The test and gold standard are measured independently (blind) of each other; - The test and gold standard are applied as close together in time as possible; - Results are reported for all patients that are entered into the study; - A pre-diagnosis is made and reported

### Hierarchy of research design

- I Properly conducted randomized controlled trial (RCT)
- II-1: Well-designed controlled trial without randomization
- II-2: Well-designed cohort or case-control analytic study
- II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
- III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees