# References

1 Pignone, M. P., Rich, M., Teutsch, S., Berg, A., and Lohr, K. Screening for colorectal cancer in adults. 2002. Rockville, MD: Agency for Healthcare Research and Quality (AHRQ).
2 Pignone M, Rich M, Teutsch SM, Berg AO, Lohr KN. Screening for colorectal cancer in adults at average risk: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:132-141. [pmid: 12118972].
3 Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348:1472-1477. [pmid: 8942775].
4 Kronborg O, Fenger C, Olsen J, Jorgensen OD, Sondergaard O. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348:1467-1471. [pmid: 8942774].
5 Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328:1365-1371. [pmid: 8474513].
6 Thiis-Evensen E, Hoff GS, Sauar J, Langmark F, Majak BM, Vatn MH. Population-based surveillance by colonoscopy: effect on the incidence of colorectal cancer. Telemark Polyp Study I. Scand J Gastroenterol. 1999;34:414-420. [pmid: 10365903].
7 Selby JV, Friedman GD, Quesenberry CP Jr, Weiss NS. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-657. [pmid: 1736103].
8 Winawer SJ, Flehinger BJ, Schottenfeld D, Miller DG. Screening for colorectal cancer with fecal occult blood testing and sigmoidoscopy. J Natl Cancer Inst. 1993;85:1311-1318. [pmid: 8340943].
9 Muller AD, Sonnenberg A. Protection by endoscopy against death from colorectal cancer. A case-control study among veterans. Arch Intern Med. 1995;155:1741-1748. [pmid: 7654107].
10 Winawer SJ, Zauber AG, Ho MN, et al. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329:1977-1981. [pmid: 8247072].
11 Zauber, A. G., Lansdorp-Vogelaar, I, Wilschut, J, Knudsen, AB, van Ballegooijen, M., and Kuntz, K. M. Decison Analysis of Colorectal Cancer Screening Tests by Age to Begin, Age to End, and Screening Intervals: Report to the United States Preventive Services Task from the Cancer Intervention and Surveillance Modeling Network (CISNET) for July 2007.
12 American Cancer Society. Colorectal Cancer Facts and Figures Special Edition 2005. Atlanta: American Cancer Society, 2005.
13 Edwards BK, Brown ML, Wingo PA, et al. Annual report to the nation on the status of cancer, 1975-2002, featuring population-based trends in cancer treatment. J Natl Cancer Inst. 2005;97:1407-1427. [pmid: 16204691].
14 AHRQ and SAMHSA. http://cancercontrol.cancer.gov. Accessed 5-17-2006
15 Surveillance Epidemiology and End Results (SEER). http://seer.cancer.gov/csr/1975_2003/sections.html. Accessed 10-16-2006
16 Ries, LAG, Eisner, MP, and Kosary, CL. SEER Cancer Statistics Review 1975-2001. Available at: http://seer.cancer.gov/csr/1975_2001/. Accessed on 10-16-2006.
17 Chu KC, Tarone RE, Chow WH, Alexander GA. Colorectal cancer trends by race and anatomic subsites, 1975 to 1991. Arch Fam Med. 1995;4:849-856. [pmid: 7551132].
18 Cooper GS, Yuan Z, Rimm AA. Racial disparity in the incidence and case-fatality of colorectal cancer: analysis of 329 United States counties. Cancer Epidemiol Biomarkers Prev. 1997;6:283-285. [pmid: 9107433].
19 Cress RD, Morris CR, Wolfe BM. Cancer of the colon and rectum in California: trends in incidence by race/ethnicity, stage, and subsite. Prev Med. 2000;31:447-453. [pmid: 11006071].
20 Troisi RJ, Freedman AN, Devesa SS. Incidence of colorectal carcinoma in the U.S.: an update of trends by gender, race, age, subsite, and stage, 1975-1994. Cancer. 1999;85:1670-1676. [pmid: 10223559].
21 Ward E, Jemal A, Cokkinides V, et al. Cancer disparities by race/ethnicity and socioeconomic status. CA Cancer J Clin. 2004;54:78-93. [pmid: 15061598].
22 Irby K, Anderson WF, Henson DE, Devesa SS. Emerging and widening colorectal carcinoma disparities between Blacks and Whites in the United States (1975-2002). Cancer Epidemiol Biomarkers Prev. 2006;15:792-797. [pmid: 16614125].
23 Rabeneck L, Davila JA, El-Serag HB. Is there a true “shift” to the right colon in the incidence of colorectal cancer?. Am J Gastroenterol. 2003;98:1400-1409. [pmid: 12818288].
24 Weitz J, Koch M, Debus J, Hohler T, Galle PR, Buchler MW. Colorectal cancer. Lancet. 2005;365:153-165. [pmid: 15639298].
25 Eaden JA, Mayberry JF. Colorectal cancer complicating ulcerative colitis: a review. Am J Gastroenterol. 2000;95:2710-2719. [pmid: 11051339].
26 Schoen RE. Families at risk for colorectal cancer: risk assessment and genetic testing. J Clin Gastroenterol. 2000;31:114-120. [pmid: 10993425].
27 Winawer SJ. Screening of colorectal cancer: progress and problems. Recent Results Cancer Res. 2005;166:231-244. [pmid: 15648193].
28 Duncan JL, Kyle J. Family incidence of carcinoma of the colon and rectum in north-east Scotland. Gut. 1982;23:169-171. [pmid: 7068040].
29 Fuchs CS, Giovannucci EL, Colditz GA, Hunter DJ, Speizer FE, Willett WC. A prospective study of family history and the risk of colorectal cancer. N Engl J Med. 1994;331:1669-1674. [pmid: 7969357].
30 Johns LE, Houlston RS. A systematic review and meta-analysis of familial colorectal cancer risk. Am J Gastroenterol. 2001;96:2992-3003. [pmid: 11693338].
31 Kune GA, Kune S, Watson LF. The Melbourne Colorectal Cancer Study. Characterization of patients with a family history of colorectal cancer. Dis Colon Rectum. 1987;30:600-606. [pmid: 3622163].
32 Negri E, Braga C, La Vecchia C, et al. Family history of cancer and risk of colorectal cancer in Italy. Br J Cancer. 1998;77:174-179. [pmid: 9459165].
33 Ponz de LM, Antonioli A, Ascari A, Zanghieri G, Sacchetti C. Incidence and familial occurrence of colorectal cancer and polyps in a health-care district of northern Italy. Cancer. 1987;60:2848-2859. [pmid: 3677018].
34 Rozen P, Fireman Z, Figer A, Legum C, Ron E, Lynch HT. Family history of colorectal cancer as a marker of potential malignancy within a screening program. Cancer. 1987;60:248-254. [pmid: 3036327].
35 Slattery ML, Kerber RA. Family history of cancer and colon cancer risk: the Utah Population Database. J Natl Cancer Inst. 1994;86:1618-1626. [pmid: 7932826].
36 St John DJ, McDermott FT, Hopper JL, Debney EA, Johnson WR, Hughes ES. Cancer risk in relatives of patients with common colorectal cancer. Ann Intern Med. 1993;118:785-790. [pmid: 8470852].
37 Winawer SJ, Zauber AG, Gerdes H, et al. Risk of colorectal cancer in the families of patients with adenomatous polyps. National Polyp Study Workgroup. N Engl J Med. 1996;334:82-87. [pmid: 8531963].
38 Giovannucci E. Modifiable risk factors for colon cancer. Gastroenterol Clin North Am. 2002;31:925-943. [pmid: 12489270].
39 Chen CD, Yen MF, Wang WM, Wong JM, Chen TH. A case-cohort study for the disease natural history of adenoma-carcinoma and de novo carcinoma and surveillance of colon and rectum after polypectomy: implication for efficacy of colonoscopy. Br J Cancer. 2003;88:1866-1873. [pmid: 12799628].
40 Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review. JAMA. 2003;289(10):1288-96. [pmid: 12633191].
41 Galiatsatos P, Foulkes WD. Familial adenomatous polyposis. Am J Gastroenterol. 2006;101:385-398. [pmid: 16454848].
42 Lynch HT, Smyrk T. Hereditary nonpolyposis colorectal cancer (Lynch syndrome). An updated review. Cancer. 1996;78:1149-1167. [pmid: 8826936].
43 Jarvinen HJ, Mecklin JP, Sistonen P. Screening reduces colorectal cancer rate in families with hereditary nonpolyposis colorectal cancer. Gastroenterology. 1995;108:1405-1411. [pmid: 7729632].
44 Citarda F, Tomaselli G, Capocaccia R, Barcherini S, Crespi M. Efficacy in standard clinical practice of colonoscopic polypectomy in reducing colorectal cancer incidence. Gut. 2001;48:812-815. [pmid: 11358901].
45 Newcomb PA, Norfleet RG, Storer BE, Surawicz TS, Marcus PM. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84:1572-1575. [pmid: 1404450].
46 Muller AD, Sonnenberg A. Prevention of colorectal cancer by flexible endoscopy and polypectomy. A case-control study of 32,702 veterans. Ann Intern Med. 1995;123:904-910. [pmid: 7486484].
47 Robertson DJ, Greenberg ER, Beach M, et al. Colorectal cancer in patients under close colonoscopic surveillance. Gastroenterology. 2005;129:34-41. [pmid: 16012932].
48 Rex DK, Kahi CJ, Levin B, et al. Guidelines for colonoscopy surveillance after cancer resection: a consensus update by the American Cancer Society and US Multi-Society Task Force on Colorectal Cancer. CA Cancer J Clin. 2006;56:160-167. [pmid: 16737948].
49 Pabby A, Schoen RE, Weissfeld JL, et al. Analysis of colorectal cancer occurrence during surveillance colonoscopy in the dietary Polyp Prevention Trial.[see comment]. Gastrointestinal Endoscopy. 2005;61(3):385-91. [pmid: 15758908].
50 Schatzkin A, Lanza E, Corle D, et al. Lack of effect of a low-fat, high-fiber diet on the recurrence of colorectal adenomas. Polyp Prevention Trial Study Group.[see comment]. New England Journal of Medicine. 2000;342(16):1149-55. [pmid: 10770979].
51 Alberts DS, Martinez ME, Roe DJ, et al. Lack of effect of a high-fiber cereal supplement on the recurrence of colorectal adenomas. Phoenix Colon Cancer Prevention Physicians' Network. N Engl J Med. 2000;342:1156-1162. [pmid: 10770980].
52 Rex DK. Maximizing detection of adenomas and cancers during colonoscopy. American Journal of Gastroenterology. 2006;101(12):2866-77. [pmid: 17227527].
53 Schoenfeld P. Small and diminutive polyps: implications for colorectal cancer screening with computed tomography colonography. Clinical Gastroenterology & Hepatology. 2006;4(3):293-5. [pmid: 16527690].
54 Schoen RE, Weissfeld JL, Pinsky PF, Riley T. Yield of advanced adenoma and cancer based on polyp size detected at screening flexible sigmoidoscopy. Gastroenterology. 2006;131(6):1683-9. [pmid: 17188959].
55 Stryker SJ, Wolff BG, Culp CE, Libbe SD, Ilstrup DM, MacCarty RL. Natural history of untreated colonic polyps. Gastroenterology. 1987;93:1009-1013. [pmid: 3653628].
56 Hofstad B, Vatn MH, Andersen SN, et al. Growth of colorectal polyps: redetection and evaluation of unresected polyps for a period of three years. Gut. 1996;39:449-456. [pmid: 8949653].
57 Bersentes K, Fennerty MB, Sampliner RE, Garewal HS. Lack of spontaneous regression of tubular adenomas in two years of follow-up. Am J Gastroenterol. 1997;92:1117-1120. [pmid: 9219781].
58 Anderson JC, Alpern Z, Messina CR, et al. Predictors of proximal neoplasia in patients without distal adenomatous pathology. Am J Gastroenterol. 2004;99:472-477. [pmid: 15056088].
59 Imperiale TF, Wagner DR, Lin CY, Larkin GN, Rogge JD, Ransohoff DF. Risk of advanced proximal neoplasms in asymptomatic adults according to the distal colorectal findings. N Engl J Med. 2000;343:169-174. [pmid: 10900275].
60 Lieberman DA, Weiss DG, Bond JH, Ahnen DJ, Garewal H, Chejfec G. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. 2000;343:162-168. [pmid: 10900274].
61 Schoenfeld P, Cash B, Flood A, et al. Colonoscopic screening of average-risk women for colorectal neoplasia. N Engl J Med. 2005;352:2061-2068. [pmid: 15901859].
62 Foutch PG, Mai H, Pardy K, DiSario JA, Manne RK, Kerr D. Flexible sigmoidoscopy may be ineffective for secondary prevention of colorectal cancer in asymptomatic, average-risk men. Dig Dis Sci. 1991;36:924-928. [pmid: 2070706].
63 Rex DK, Smith JJ, Ulbright TM, Lehman GA. Distal colonic hyperplastic polyps do not predict proximal adenomas in asymptomatic average-risk subjects. Gastroenterology. 1992;102:317-319. [pmid: 1727766].
64 Foutch PG, DiSario JA, Pardy K, Mai HD, Manne RK. The sentinel hyperplastic polyp: a marker for synchronous neoplasia in the proximal colon. Am J Gastroenterol. 1991;86:1482-1485. [pmid: 1928041].
65 Kadakia SC, Wrobleski CS, Kadakia AS, Meier NJ. Prevalence of proximal colonic polyps in average-risk asymptomatic patients with negative fecal occult blood tests and flexible sigmoidoscopy. Gastrointest Endosc. 1996;44:112-117. [pmid: 8858314].
66 Lieberman DA, Smith FW. Screening for colon malignancy with colonoscopy. Am J Gastroenterol. 1991;86:946-951. [pmid: 1858758].
67 Johnson DA, Gurney MS, Volpe RJ, et al. A prospective study of the prevalence of colonic neoplasms in asymptomatic patients with an age-related risk. Am J Gastroenterol. 1990;85:969-974. [pmid: 2375325].
68 Rex DK, Lehman GA, Hawes RH, Ulbright TM, Smith JJ. Screening colonoscopy in asymptomatic average-risk persons with negative fecal occult blood tests. Gastroenterology. 1991;100:64-67. [pmid: 1796931].
69 DiSario JA, Foutch PG, Mai HD, Pardy K, Manne RK. Prevalence and malignant potential of colorectal polyps in asymptomatic, average-risk men. Am J Gastroenterol. 1991;86:941-945. [pmid: 1858757].
70 Moravec M, Lieberman D, Holub J, Michaels L, Eisen G. Rate of Advanced Pathologic Features in 6–9mm Polyps in Patients Referred for Colonoscopy Screening. Gastrointest Endosc. 2007;65(5):822.
71 Lawrance IC, Sherrington C, Murray K. Poor correlation between clinical impression, the small colonic polyp and their neoplastic risk. Journal of Gastroenterology & Hepatology. 2006;21(3):563-8. [pmid: 16638099].
72 Butterly LF, Chase MP, Pohl H, Fiarman GS. Prevalence of clinically important histology in small adenomas. Clin Gastroenterol Hepatol. 2006;4:343-348. [pmid: 16527698].
73 Church JM. Clinical significance of small colorectal polyps. Dis Colon Rectum. 2004;47:481-485. [pmid: 14994108].
74 Odom SR, Duffy SD, Barone JE, Ghevariya V, McClane SJ. The rate of adenocarcinoma in endoscopically removed colorectal polyps. Am Surg. 2005;71:1024-1026. [pmid: 16447472].
75 Weston AP, Campbell DR. Diminutive colonic polyps: histopathology, spatial distribution, concomitant significant lesions, and treatment complications. Am J Gastroenterol. 1995;90:24-28. [pmid: 7801943].
76 Atkin WS, Morson BC, Cuzick J. Long-term risk of colorectal cancer after excision of rectosigmoid adenomas. N Engl J Med. 1992;326:658-662. [pmid: 1736104].
77 Muto T, Bussey HJ, Morson BC. The evolution of cancer of the colon and rectum. Cancer. 1975;36:2251-2270. [pmid: 1203876].
78 Nusko G, Mansmann U, tendorf-Hofmann A, Groitl H, Wittekind C, Hahn EG. Risk of invasive carcinoma in colorectal adenomas assessed by size and site. Int J Colorectal Dis. 1997;12:267-271. [pmid: 9401839].
79 Gillespie PE, Chambers TJ, Chan KW, Doronzo F, Morson BC, Williams CB. Colonic adenomas—a colonoscopy survey. Gut. 1979;20:240-245. [pmid: 437557].
80 Shinya H, Wolff WI. Morphology, anatomic distribution and cancer potential of colonic polyps. Ann Surg. 1979;190:679-683. [pmid: 518167].
81 Gondal G, Grotmol T, Hofstad B, Bretthauer M, Eide TJ, Hoff G. The Norwegian Colorectal Cancer Prevention (NORCCAP) screening study: baseline findings and implementations for clinical work-up in age groups 50–64 years. Scandinavian Journal of Gastroenterology. 2003;38(6):635-42. [pmid: 12825872].
82 Segnan N, Senore C, Andreoni B, et al. Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”—SCORE. J Natl Cancer Inst. 2002;94:1763-1772. [pmid: 12464648].
83 UK Flexible Sigmoidoscopy Screening Trial Investigators. Single flexible sigmoidoscopy screening to prevent colorectal cancer: baseline findings of a UK multicentre randomised trial. Lancet. 2002;359(9314):1291-300. [pmid: 11965274].
84 Soetikno RM, Kaltenbach T, Rouse RV, et al. Prevalence of nonpolypoid (flat and depressed) colorectal neoplasms in asymptomatic and symptomatic adults. JAMA. 2008;299:1027-1035. [pmid: 18319413].
85 Stergiou N, Frenz MB, Menke D, Riphaus A, Wehrmann T. Reduction of miss rates of colonic adenomas by zoom chromoendoscopy. International Journal of Colorectal Disease. 2006;21(6):560-5. [pmid: 16283340].
86 Trecca A, Gaj F, Pasciuto A, Serafini S, Bella A. Advanced diagnostic tools: virtual colonoscopy and magnifying chromoendoscopy. Techniques in Coloproctology. 2004;8(Suppl):82.
87 Le RM, Coron E, Parlier D, et al. High resolution colonoscopy with chromoscopy versus standard colonoscopy for the detection of colonic neoplasia: a randomized study. Clin Gastroenterol Hepatol. 2006;4:349-354. [pmid: 16527699].
88 Sonwalkar S, Rotimi O, Rembacken BJ. Characterization of colonic polyps at conventional (nonmagnifying) colonoscopy after spraying with 0.2 % indigo carmine dye. Endoscopy. 2006;38:1218-1223. [pmid: 17163322].
89 Rembacken BJ, Fujii T, Cairns A, et al. Flat and depressed colonic neoplasms: a prospective study of 1000 colonoscopies in the UK.[see comment]. Lancet. 2000;355(9211):1211-4. [pmid: 10770302].
90 Zauber AG, O'Brien MJ, Winawer SJ. On finding flat adenomas: is the search worth the gain?. Gastroenterology. 2002;122:839-840. [pmid: 11878297].
91 O'Brien MJ, Winawer SJ, Zauber AG, et al. Flat adenomas in the National Polyp Study: is there increased risk for high-grade dysplasia initially or during surveillance?. Clinical Gastroenterology & Hepatology. 2004;2(10):905-11. [pmid: 15476154].
92 O'Brien MJ, Winawer S, Zauber AG. Blinded assessment of the flat adenoma in the National Polyp Study (NPS) does not demonstrate an excess risk for high grade dysplasia initially or for advanced adenomas at surveillance. Am J Gastroenterol. 2001;120:A96.
93 Sano Y, Fujii T, Oda Y, et al. A multicenter randomized controlled trial designed to evaluate follow-up surveillance strategies for colorectal cancer: the Japan Polyp Study. Digestive Endoscopy. 2004;16:376-378.
94 Hewitson P, Glasziou P, Irwig L, Towler B, Watson E. Screening for colorectal cancer using the faecal occult blood test, Hemoccult. Cochrane Database Syst Rev. 2007;CD001216.
95 Smith RA. Cancer screening in the USA. Journal of Medical Screening. 2006;13(Suppl 1):S48-53. [pmid: 17227643].
96 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124:544-560. [pmid: 12557158].
97 Davila RE, Rajan E, Baron TH, et al. ASGE guideline: colorectal cancer screening and surveillance. Gastrointest Endosc. 2006;63:546-557. [pmid: 16564851].
98 Ko C, Hyman NH. Practice parameter for the detection of colorectal neoplasms: an interim report (revised). Dis Colon Rectum. 2006;49:299-301. [pmid: 16421663].
99 Breen N, Wagener DK, Brown ML, Davis WW, Ballard-Barbash R. Progress in cancer screening over a decade: results of cancer screening from the 1987, 1992, and 1998 National Health Interview Surveys. J Natl Cancer Inst. 2001;93:1704-1713. [pmid: 11717331].
100 Klabunde CN, Frame PS, Meadow A, Jones E, Nadel M, Vernon SW. A national survey of primary care physicians' colorectal cancer screening recommendations and practices. Prev Med. 2003;36:352-362. [pmid: 12634026].
101 Yeazel MW, Church TR, Jones RM, et al. Colorectal cancer screening adherence in a general population. Cancer Epidemiology, Biomarkers & Prevention. 2004;13:654-657.
102 Smith RA, Cokkinides V, Eyre HJ. Cancer screening in the United States, 2007: a review of current guidelines, practices, and prospects. CA Cancer J Clin. 2007;57:90-104. [pmid: 17392386].
103 Meissner HI, Breen N, Klabunde CN, Vernon SW. Patterns of colorectal cancer screening uptake among men and women in the United States. Cancer Epidemiology, Biomarkers & Prevention. 2006;15(2):389-94.
104 Use of colorectal cancer tests—United States, 2002, 2004, and 2006. MMWR Morb Mortal Wkly Rep. 2008;57:253–258.
105 Centers for Disease Control and Prevention (CDC). Increased use of colorectal cancer tests—United States, 2002 and 2004. MMWR - Morbidity & Mortality Weekly Report. 2006;55:308-311. [pmid: 16557215].
106 Ananthakrishnan AN, Schellhase KG, Sparapani RA, Laud PW, Neuner JM. Disparities in colon cancer screening in the Medicare population. Archives of Internal Medicine. 2007;167(3):258-64. [pmid: 17296881].
107 Pollack, L. A., Blackman, D. K., Wilson, K. M., Seeff, L. C., and Nadel, M. R. Colorectal cancer test use among Hispanic and non-Hispanic U.S. populations. Available at URL: http://www.cdc.gov/pcd/issues/2006/apr/05_120.htm. Accessed on 9-22-0008.
108 Schootman M, Jeffe DB, Baker EA, Walker MS. Effect of area poverty rate on cancer screening across US communities. Journal of Epidemiology & Community Health. 2006;60(3):202-7. [pmid: 16476748].
109 Lafata JE, Williams LK, Ben Menachem T, Moon C, Divine G. Colorectal carcinoma screening procedure use among primary care patients. Cancer. 2005;104:1356-1361. [pmid: 16092119].
110 Klabunde C, Breen N, Meissner H, Subramanian S. Use of colonoscopy for colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. 2005;14:2279-2280. [pmid: 16172249].
111 Collins JF, Lieberman DA, Durbin TE, Weiss DG. Veterans Affairs Cooperative. Accuracy of screening for fecal occult blood on a single stool sample obtained by digital rectal examination: a comparison with recommended sampling practice. Ann Intern Med. 2005;142:81-85. [pmid: 15657155].
112 Nadel MR, Shapiro JA, Klabunde CN, et al. A national survey of primary care physicians' methods for screening for fecal occult blood. Ann Intern Med. 2005;142:86-94. [pmid: 15657156].
113 Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for Colonoscopy Surveillance After Polypectomy: A Consensus Update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. Gastroenterology. 2006;130(6):1872-85. [pmid: 16697750].
114 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
115 Rockey DC, Paulson E, Niedzwiecki D, et al. Analysis of air contrast barium enema, computed tomographic colonography, and colonoscopy: prospective comparison. Lancet. 2005;365:305-311. [pmid: 15664225].
116 Mulhall BP, Veerappan GR, Jackson JL. Meta-analysis: computed tomographic colonography. Ann Intern Med. 2005;142:635-650. [pmid: 15838071].
117 Banerjee S, Van Dam J. CT colonography for colon cancer screening. Gastrointest Endosc. 2006;63:121-133. [pmid: 16377329].
118 Blue Cross Blue Shield Association. CT colonography (‘virtual colonoscopy’) for colon cancer screening. Volume 19. No. 6. 2004. Chicago IL: Blue Cross Blue Shield Association (BCBS).
119 HAYES and Inc. Computed Tomography Colonography (Virtual Colonoscopy). 2006. Lansdale, PA: HAYES, Inc.
120 Sosna J, Morrin MM, Kruskal JB, Lavin PT, Rosen MP, Raptopoulos V. CT colonography of colorectal polyps: a metaanalysis. AJR Am J Roentgenol. 2003;181:1593-1598. [pmid: 14627580].
121 National Institute of Health and Clinical Excellence. Computed Tomographic Colonography. Report No. IPG129. 2005. National Institute of Health and Clinical Excellence.
122 Soares-Weiser, K, Burch, J, Duffy, S, St John, J, Smith, Stephen, Westwood, M, and Kleijnen, J. Diagnostic accuracy and cost-effectiveness of faecal occult blood tests (fobt) used in screening for colorectal cancer: a systematic review. 2007. University of York: Centre for Reviews and Dissemination.
123 Blue Cross Blue Shield Association. Immunochemical versus guaiac fecal occult blood tests. Volume 19. No 5. 2004. Chicago IL: Blue Cross Blue Shield Association (BCBS).
124 Blue Cross Blue Shield Association. Fecal DNA Analysis for Colorectal Cancer Screening. Volume 21. No. 6. 2006. Chicago IL: Blue Cross Blue Shield Association (BCBS).
125 HAYES and Inc. Fecal DNA testing for colorectal cancer screening and monitoring. 2002. Lansdale, PA: HAYES, Inc.
126 Haug U, Brenner H. New stool tests for colorectal cancer screening: a systematic review focusing on performance characteristics and practicalness. Int J Cancer. 2005;117:169-176. [pmid: 15880368].
127 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44:1271-1278. [pmid: 1834807].
128 National Institute for Clinical Excellence. Guideline Development Methods: Information for National Collaborating Centres and Guideline Developers. 2004. London: National Institute for Clinical Excellence.
129 Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. 2008;61:41-51. [pmid: 18083461].
130 Turner RM, Omar RZ, Yang M, Goldstein H, Thompson SG. A multilevel model framework for meta-analysis of clinical trials with binary outcomes. Stat Med. 2000;19:3417-3432. [pmid: 11122505].
131 Kronborg O, Jorgensen OD, Fenger C, Rasmussen M. Randomized study of biennial screening with a faecal occult blood test: results after nine screening rounds. Scand J Gastroenterol. 2004;39:846-851. [pmid: 15513382].
132 Scholefield JH, Moss S, Sufi F, Mangham CM, Hardcastle JD. Effect of faecal occult blood screening on mortality from colorectal cancer: results from a randomised controlled trial. Gut. 2002;50:840-844. [pmid: 12010887].
133 Kewenter J, Brevinge H, Engaras B, Haglind E, Ahren C. Results of screening, rescreening, and follow-up in a prospective randomized study for detection of colorectal cancer by fecal occult blood testing. Results for 68,308 subjects. Scand J Gastroenterol. 1994;29:468-473. [pmid: 8036464].
134 Jorgensen OD, Kronborg O, Fenger C. A randomised study of screening for colorectal cancer using faecal occult blood testing: results after 13 years and seven biennial screening rounds. Gut. 2002;50:29-32. [pmid: 11772963].
135 Mandel JS, Church TR, Ederer F, Bond JH. Colorectal cancer mortality: effectiveness of biennial screening for fecal occult blood. J Natl Cancer Inst. 1999;91:434-437. [pmid: 10070942].
136 Pickhardt PJ, Choi JR, Hwang I, et al. Computed tomographic virtual colonoscopy to screen for colorectal neoplasia in asymptomatic adults. New England Journal of Medicine. 2003;349(23):2191-200. [pmid: 14657426].
137 Kim SH, Lee JM, Eun HW, et al. Two- versus Three-dimensional Colon Evaluation with Recently Developed Virtual Dissection Software for CT Colonography. Radiology. 2007;244(3):852-64. [pmid: 17709833].
138 Johnson CD, Fletcher JG, MacCarty RL, et al. Effect of slice thickness and primary 2D versus 3D virtual dissection on colorectal lesion detection at CT colonography in 452 asymptomatic adults. AJR American Journal of Roentgenology. 2007;189(3):672-80. [pmid: 17715116].
139 Ho, C., Jacobs, P., Sandha, G., Noorani, H. Z., and Skidmore, B. Non-physicians performing screening flexible sigmoidoscopy: clinical efficacy and cost-effectiveness. 2006. Ottawa: Canadian Coordinating Office for Health Technology Assessment (CCOHTA).
140 Adams, E. Bibliography: Screening colonoscopy by mid-level practitioners. 2004. Boston: Technology Assessment Unit, Office of Patient Care Services, US Department of Veterans Affairs (VATAP).
141 Schoenfeld P, Lipscomb S, Crook J, et al. Accuracy of polyp detection by gastroenterologists and nurse endoscopists during flexible sigmoidoscopy: a randomized trial. Gastroenterology. 1999;117:312-318. [pmid: 10419911].
142 Schoen RE, Pinsky PF, Weissfeld JL, et al. Results of repeat sigmoidoscopy 3 years after a negative examination. JAMA. 2003;290:41-48. [pmid: 12837710].
143 Burke CA, Elder K, Lopez R. Screening for colorectal cancer with flexible sigmoidoscopy: is a 5-yr interval appropriate? A comparison of the detection of neoplasia 3 yr versus 5 yr after a normal examination. American Journal of Gastroenterology. 2006;101(6):1329-32. [pmid: 16771957].
144 Betes-Ibanez M, Munoz-Navas MA, Duque JM, et al. Diagnostic value of distal colonic polyps for prediction of advanced proximal neoplasia in an average-risk population undergoing screening colonoscopy. Gastrointestinal Endoscopy. 2004;59(6):634-41. [pmid: 15114305].
145 Ikeda Y, Mori M, Miyazaki M, Yoshizumi T, Maehara Y, Sugimachi K. Significance of small distal adenoma for detection of proximal neoplasms in the colorectum. Gastrointest Endosc. 2000;52:358-361. [pmid: 10968850].
146 Imperiale TF, Wagner DR, Lin CY, Larkin GN, Rogge JD, Ransohoff DF. Using risk for advanced proximal colonic neoplasia to tailor endoscopic screening for colorectal cancer. Ann Intern Med. 2003;139:959-965. [pmid: 14678915].
147 Weissfeld JL, Schoen RE, Pinsky PF, et al. Flexible sigmoidoscopy in the PLCO cancer screening trial: results from the baseline screening examination of a randomized trial. J Natl Cancer Inst. 2005;97:989-997. [pmid: 15998952].
148 Macari M, Milano A, Lavelle M, Berman P, Megibow AJ. Comparison of time-efficient CT colonography with two- and three-dimensional colonic evaluation for detecting colorectal polyps. AJR Am J Roentgenol. 2000;174:1543-1549. [pmid: 10845478].
149 Macari M, Bini EJ, Jacobs SL, et al. Colorectal polyps and cancers in asymptomatic average-risk patients: evaluation with CT colonography. Radiology. 2004;230(3):629-36. [pmid: 14739311].
150 Rex DK, Vining D, Kopecky KK. An initial experience with screening for colon polyps using spiral CT with and without CT colography (virtual colonoscopy). Gastrointest Endosc. 1999;50:309-313. [pmid: 10462648].
151 Pickhardt P, Lee A, Taylor A, Michel S, Winter T. Primary 2D versus Primary 3D Polyp Detection at Screening CT Colonography. Am J Roentgenol. 2007;189:1451-1456. [pmid: 18029884].
152 Pickhardt PJ, Nugent PA, Choi JR, Schindler WR. Flat colorectal lesions in asymptomatic adults: implications for screening with CT virtual colonoscopy. AJR American Journal of Roentgenology. 2004;183(5):1343-7. [pmid: 15505301].
153 Dachman AH, Lefere P, Gryspeerdt S, Morin M. CT colonography: visualization methods, interpretation, and pitfalls. Radiologic Clinics of North America. 2007;45(2):347-59. [pmid: 17502222].
154 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-1066. [pmid: 10493205].
155 ECRI. Fecal DNA testing for colorectal cancer (CRC). 2006. ECRI.
156 Itzkowitz SH, Jandorf L, Brand R, et al. Improved fecal DNA test for colorectal cancer screening. Clinical Gastroenterology & Hepatology. 2007;5(1):111-7. [pmid: 17161655].
157 Haug U, Hillebrand T, Bendzko P, et al. Mutant-enriched PCR and allele-specific hybridization reaction to detect K-ras mutations in stool DNA: high prevalence in a large sample of older adults. Clin Chem. 2007;53:787-790. [pmid: 17317884].
158 Imperiale TF, Ransohoff DF, Itzkowitz SH, Turnbull BA, Ross ME. Colorectal Cancer Study Group. Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. New England Journal of Medicine. 2004;351(26):2704-14. [pmid: 15616205].
159 Allison JE, Sakoda LC, Levin TR, et al. Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. 2007;99:1462-1470. [pmid: 17895475].
160 Allison JE, Tekawa IS, Ransom LJ, Adrain AL. A comparison of fecal occult-blood tests for colorectal-cancer screening. N Engl J Med. 1996;334:155-159. [pmid: 8531970].
161 Cheng TI, Wong JM, Hong CF, et al. Colorectal cancer screening in asymptomaic adults: comparison of colonoscopy, sigmoidoscopy and fecal occult blood tests. J Formos Med Assoc. 2002;101:685-690. [pmid: 12517041].
162 Levi Z, Rozen P, Hazazi R, et al. A quantitative immunochemical fecal occult blood test for colorectal neoplasia. Ann Intern Med. 2007;146:244-255. [pmid: 17310048].
163 Morikawa T, Kato J, Yamaji Y, Wada R, Mitsushima T, Shiratori Y. A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. 2005;129:422-428. [pmid: 16083699].
164 Nakama H, Zhang B, Fattah AS. A cost-effective analysis of the optimum number of stool specimens collected for immunochemical occult blood screening for colorectal cancer. Eur J Cancer. 2000;36:647-650. [pmid: 10738130].
165 Itoh M, Takahashi K, Nishida H, Sakagami K, Okubo T. Estimation of the optimal cut off point in a new immunological faecal occult blood test in a corporate colorectal cancer screening programme. J Med Screen. 1996;3:66-71. [pmid: 8849762].
166 Launoy GD, Bertrand HJ, Berchi C, et al. Evaluation of an immunochemical fecal occult blood test with automated reading in screening for colorectal cancer in a general average-risk population. International Journal of Cancer. 2005;115(3):493-6.
167 Nakama H, Kamijo N, bdul Fattah AS, Zhang B. Validity of immunological faecal occult blood screening for colorectal cancer: a follow up study. Journal of Medical Screening. 1996;3(2):63-5. [pmid: 8849761].
168 Liu HH, Huang TW, Chen HL, Wang TH, Lin JT. Clinicopathologic significance of immunohistochemical fecal occult blood test in subjects receiving bidirectional endoscopy. Hepatogastroenterology. 2003;50:1390-1392. [pmid: 14571744].
169 Nakama H, Yamamoto M, Kamijo N, et al. Colonoscopic evaluation of immunochemical fecal occult blood test for detection of colorectal neoplasia. Hepatogastroenterology. 1999;46:228-231. [pmid: 10228797].
170 Korman LY, Overholt BF, Box T, Winker CK. Perforation during colonoscopy in endoscopic ambulatory surgical centers. Gastrointestinal Endoscopy. 2003;58(4):554-7. [pmid: 14520289].
171 Levin TR, Zhao W, Conell C, et al. Complications of colonoscopy in an integrated health care delivery system. Annals of Internal Medicine. 2006;145(12):880-6. [pmid: 17179057].
172 Rathgaber SW, Wick TM. Colonoscopy completion and complication rates in a community gastroenterology practice. Gastrointestinal Endoscopy. 2006;64(4):556-62. [pmid: 16996349].
173 Atkin WS, Hart A, Edwards R, et al. Uptake, yield of neoplasia, and adverse effects of flexible sigmoidoscopy screening. Gut. 1998;42:560-565. [pmid: 9616321].
174 Cotterill M, Gasparelli R, Kirby E. Colorectal cancer detection in a rural community. Development of a colonoscopy screening program. Can Fam Physician. 2005;51:1224-1228. [pmid: 16190175].
175 Kewenter J, Brevinge H. Endoscopic and surgical complications of work-up in screening for colorectal cancer. Dis Colon Rectum. 1996;39:676-680. [pmid: 8646956].
176 Ko CW, Riffle S, Shapiro JA, et al. Incidence of minor complications and time lost from normal activities after screening or surveillance colonoscopy. Gastrointest Endosc. Apr. 2007;65(4):648-56. [pmid: 17173914].
177 Ko CW, Riffle S, Morris CG, Michaels L, Holub JL, Shapiro J, Seeff L, Lieberman D. Complications after Screening and Surveillance Colonoscopy. Gastroenterology. 2007;132:A149.
178 Lee YC, Wang HP, Chiu HM, et al. Factors determining post-colonoscopy abdominal pain: prospective study of screening colonoscopy in 1000 subjects. Journal of Gastroenterology & Hepatology. 2006;21(10):1575-80. [pmid: 16928219].
179 Nelson DB, McQuaid KR, Bond JH, Lieberman DA, Weiss DG, Johnston TK. Procedural success and complications of large-scale screening colonoscopy. Gastrointestinal Endoscopy. 2002;55(3):307-14. [pmid: 11868001].
180 Newcomer MK, Shaw MJ, Williams DM, Jowell PS. Unplanned work absence following outpatient colonoscopy. J Clin Gastroenterol. 1999;29:76-78. [pmid: 10405238].
181 Robinson MH, Hardcastle JD, Moss SM, et al. The risks of screening: data from the Nottingham randomised controlled trial of faecal occult blood screening for colorectal cancer. Gut. 1999;45:588-592. [pmid: 10486370].
182 Kim DH, Pickhardt PJ, Taylor AJ, et al. CT colonography versus colonoscopy for the detection of advanced neoplasia. N Engl J Med. 2007;357:1403-1412. [pmid: 17914041].
183 Ko, C. W. Personal Communication. 6-1-2007.
184 Jain A, Falzarano J, Jain A, Decker R, Okubo G, Fujiwara D. Outcome of 5,000 flexible sigmoidoscopies done by nurse endoscopists for colorectal screening in asymptomatic patients. Hawaii Med J. 2002;61:118-120. [pmid: 12148407].
185 Levin TR, Conell C, Shapiro JA, Chazan SG, Nadel MR, Selby JV. Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123(6):1786-92. [pmid: 12454834].
186 Wallace MB, Kemp JA, Meyer F, et al. Screening for colorectal cancer with flexible sigmoidoscopy by nonphysician endoscopists. Am J Med. 1999;107:214-218. [pmid: 10492313].
187 Viiala CH, Olynyk JK. Outcomes after 10 years of a community-based flexible sigmoidoscopy screening program for colorectal carcinoma. Med J Aust. 2007;187:274-277. [pmid: 17767431].
188 Hoff G, Thiis-Evensen E, Grotmol T, Sauar J, Vatn MH, Moen IE. Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983-1996. Eur J Cancer Prev. 2001;10:131-137. [pmid: 11330453].
189 Edwards JT, Mendelson RM, Fritschi L, et al. Colorectal neoplasia screening with CT colonography in average-risk asymptomatic subjects: community-based study. Radiology. 2004;230(2):459-64. [pmid: 14688402].
190 Pickhardt PJ. Incidence of colonic perforation at CT colonography: review of existing data and implications for screening of asymptomatic adults. Radiology. 2006;239(2):313-6. [pmid: 16641348].
191 Sosna J, Blachar A, Amitai M, et al. Colonic perforation at CT colonography: assessment of risk in a multicenter large cohort. Radiology. 2006;239:457-463. [pmid: 16543590].
192 Jensch S, van Gelder RE, Venema HW, et al. Effective radiation doses in CT colonography: results of an inventory among research institutions. Eur Radiol. 2006;16:981-987. [pmid: 16418863].
193 van Gelder RE, Venema HW, Serlie IW, et al. CT colonography at different radiation dose levels: feasibility of dose reduction. Radiology. 2002;224:25-33. [pmid: 12091658].
194 Brenner H, Arndt V, Stegmaier C, Ziegler H, Sturmer T. Reduction of clinically manifest colorectal cancer by endoscopic screening: empirical evaluation and comparison of screening at various ages. European Journal of Cancer Prevention. 2005;14(3):231-7. [pmid: 15901991].
195 Buls N, de MJ, Covens P, Stadnik T. Health screening with CT: prospective assessment of radiation dose and associated detriment. Jbr-Btr: Organe de la Societe Royale Belge de Radiologie. 2005;88:12-16.
196 Florie J, van Gelder RE, Stoker J. Colonography by computed tomography. European Journal of Gastroenterology & Hepatology. 2005;17:809-813. [pmid: 16003128].
197 Frush DP, Applegate K. Computed tomography and radiation: understanding the issues. J Am Coll Radiol. 2004;1:113-119. [pmid: 17411538].
198 Macari M, Bini EJ. CT colonography: where have we been and where are we going?. Radiology. 2005;237(3):819-33. [pmid: 16237143].
199 O'Hare A, Fenlon H. Virtual colonoscopy in the detection of colonic polyps and neoplasms. Best Practice & Research in Clinical Gastroenterology. 2006;79–92.
200 Prokop M. Cancer screening with CT: dose controversy. Eur Radiol. 2005;15:D55-D61. [pmid: 16479648].
201 van Gelder RE, Florie J, Stoker J. Colorectal cancer screening and surveillance with CT colonography: current controversies and obstacles. Abdominal Imaging Feb. 2005;30(1):5-12.
202 Taylor T, Williamson S, Wardle J, Borrill J, Sutton S, Atkin W. Acceptability of flexible sigmoidoscopy screening in older adults in the United Kingdom. Journal of Medical Screening. 2000;7(1):38-45. [pmid: 10807146].
203 Moayyedi P, Achkar E. Does fecal occult blood testing really reduce mortality? A reanalysis of systematic review data. American Journal of Gastroenterology. 2006;101(2):380-4. [pmid: 16454847].
204 Begg CB, Bach PB. Re: All-cause mortality in randomized trials of cancer screening.[comment]. J Natl Cancer Inst. 2002;94:863-864. [pmid: 12048279].
205 Church TR, Ederer F, Mandel JS. Re: All-cause mortality in randomized trials of cancer screening.[comment]. J Natl Cancer Inst. 2002;94:861-866. [pmid: 12048277].
206 Gail MH, Katki HA. Re: All-cause mortality in randomized trials of cancer screening. J Natl Cancer Inst. 2002;94:862-866. [pmid: 12048278].
207 Kopans DB, Halpern E. Re: All-cause mortality in randomized trials of cancer screening. J Natl Cancer Inst. 2002;94:863-866. [pmid: 12048280].
208 Weiss NS, Koepsell TD. Re: All-cause mortality in randomized trials of cancer screening. J Natl Cancer Inst. 2002;94:864-865. [pmid: 12048281].
209 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. 2006;144:850-855. [pmid: 16754927].
210 National Bowel Cancer Screening Program. Available at: http://www.cancerscreening.gov.au/internet/screening/publishing.nsf/Content/bowel-1lp. Accessed on 10-16-2006.
211 Cole SR, Young GP, Esterman A, Cadd B, Morcom J. A randomised trial of the impact of new faecal haemoglobin test technologies on population participation in screening for colorectal cancer. J Med Screen. 2003;10:117-122. [pmid: 14561262].
212 Rennert G, Rennert HS, Miron E, Peterburg Y. Population colorectal cancer screening with fecal occult blood test. Cancer Epidemiology, Biomarkers & Prevention. 2001;10:1165-1168.
213 St John DJ, Young GP, Alexeyeff MA, et al. Evaluation of new occult blood tests for detection of colorectal neoplasia. Gastroenterology. 1993;104(6):1661-8. [pmid: 8500724].
214 Allison JE, Levin T, Sakoda LC, Tucker J, Tekawa IS, Pauly M. The new fecal occult blood tests have poor application sensitivity for significant polyps in average risk subjects. Gastroenterology. 2002;122:A592-A593.
215 Woolf SH. A smarter strategy? Reflections on fecal DNA screening for colorectal cancer. New England Journal of Medicine. 2004;351(26):2755-8. [pmid: 15616212].
216 U.S.Food and Drug Administration and U.S.Department of Health and Human Services. Warning Letter. Available at: http://www.fda.gov/foi/warning_letters/s6568c.htm. Accessed on 10-11-2007.
217 Decision Memo for Screening DNA Stool Test for Colorectal Cancer (CAG-00144N). Available at: http://www.cms.hhs.gov/mcd/viewdecisionmemo.asp?id=212. Accessed on 4-28-2008. Centers for Medicare & Medicaid Services.
218 Zauber, A. G., Lansdorp-Vogelaar, I, Wilschut, J, Knudsen, AB, van Ballegooijen, M., and Kuntz, K. M. Cost-effectiveness of DNA Stool Testing to Screen for Colorectal Cancer. 12-20-2007. Rockville, MD, Agency for Healthcare Research and Quality.
219 Ahlquist, D. A. Personal Communication. 10-4-2007.
220 Medical Services Advisory Committee. Faecal occult blood testing for population health screening. 2004. Canberra: Medical Services Advisory Committee (MSAC).
221 Kuehle CA, Langhorst J, Ladd SC, et al. Magnetic resonance colonography without bowel cleansing: a prospective cross sectional study in a screening population. Gut. 2007;56(8):1079-85. [pmid: 17341542].
222 Barnes, E. ACRIN trial shows VC ready for wide spread use. Available at: www.auntminnie.com/index.asp?Sec=sup&Sub=vco&Pag=dis&ItemId=77711. Accessed 9-28-2007
223 Barnes, E. Two recent studies have given new life to an old rivalry: 2D versus 3D primary reading of virtual colonoscopy (VC or CT colonography [CTC]) data. Available at: www.Auntminnie.com. Accessed 4-10-2008
224 Landeras LA, Aslam R, Yee J. Virtual colonoscopy: technique and accuracy. Radiologic Clinics of North America. 2007;45(2):333-45. [pmid: 17502221].
225 Ransohoff DF. Virtual colonoscopy—what it can do vs what it will do. JAMA. 2004;291:1772-1774. [pmid: 15082706].
226 Rockey DC, Barish M, Brill JV, et al. Standards for gastroenterologists for performing and interpreting diagnostic computed tomographic colonography. Gastroenterology. 2007;133:1005-1024. [pmid: 17678924].
227 Taylor SA, Laghi A, Lefere P, Halligan S, Stoker J. European Society of Gastrointestinal and Abdominal Radiology (ESGAR): consensus statement on CT colonography. European Radiology. 2007;17(2):575-9. [pmid: 16967260].
228 Pickhardt, P. J. Personal Communication. 5-25-2007.
229 Committee to Assess Health Risks from exposure to Low Levels of Ionizing Radiation, Board on Radiation Effects, Research Division on Earth and Life Sciences, and National Research Council of the National Academics. Health Risks from Exposure to Low Levels of Ionizing Radiation: BEIR VII, Phase 2. 2006. Washington, DC, National Academic Press.
230 Graser, A. Results from the “Munich Colorectal Cancer Prevention Trial”: Comparison of Low-dose 64 MDCT Colonography and Video Colonoscopy in a Screening Population. Radiological Society of North America Meeting November 28, 2006.
231 Cardis E, Vrijheid M, Blettner M, et al. Risk of cancer after low doses of ionising radiation: retrospective cohort study in 15 countries. BMJ. 2005;331:77. [pmid: 15987704].
232 Brenner DJ, Hall EJ. Computed tomography—an increasing source of radiation exposure. N Engl J Med. 2007;357:2277-2284. [pmid: 18046031].
233 Einstein AJ, Henzlova MJ, Rajagopalan S. Estimating risk of cancer associated with radiation exposure from 64-slice computed tomography coronary angiography. JAMA. 2007;298:317-323. [pmid: 17635892].
234 Xiong T, Richardson M, Woodroffe R, Halligan S, Morton D, Lilford RJ. Incidental lesions found on CT colonography: their nature and frequency. Br J Radiol. 2005;78:22-29. [pmid: 15673525].
235 Chin M, Mendelson R, Edwards J, Foster N, Forbes G. Computed tomographic colonography: prevalence, nature, and clinical significance of extracolonic findings in a community screening program. Am J Gastroenterol. 2005;100:2771-2776. [pmid: 16393234].
236 Gluecker TM, Johnson CD, Harmsen WS, et al. Colorectal cancer screening with CT colonography, colonoscopy, and double-contrast barium enema examination: prospective assessment of patient perceptions and preferences. Radiology. 2003;227(2):378-84. [pmid: 12732696].
237 Pickhardt PJ, Hassan C, Laghi A, Zullo A, Kim DH, Morini S. Cost-effectiveness of colorectal cancer screening with computed tomography colonography: the impact of not reporting diminutive lesions. Cancer. 2007;109(11):2213-21. [pmid: 17455218].
238 Hellstrom M, Svensson MH, Lasson A. Extracolonic and incidental findings on CT colonography (virtual colonoscopy). AJR American Journal of Roentgenology. 2004;182(3):631-8. [pmid: 14975961].
239 Hara AK, Johnson CD, Reed JE, et al. Detection of colorectal polyps with CT colography: initial assessment of sensitivity and specificity. Radiology. 1997;205:59-65. [pmid: 9314963].
240 Edwards JT, Wood CJ, Mendelson RM, Forbes GM. Extracolonic findings at virtual colonoscopy: implications for screening programs. Am J Gastroenterol. 2001;96:3009-3012. [pmid: 11693340].
241 van Rijn JC, Reitsma JB, Stoker J, Bossuyt PM, van Deventer SJ, Dekker E. Polyp miss rate determined by tandem colonoscopy: a systematic review. Am J Gastroenterol. 2006;101:343-350. [pmid: 16454841].
242 Bressler B, Paszat LF, Chen Z, Rothwell DM, Vinden C, Rabeneck L. Rates of new or missed colorectal cancers after colonoscopy and their risk factors: a population-based analysis. Gastroenterology. 2007;132:96-102. [pmid: 17241863].
243 Rex DK, Petrini JL, Baron TH, et al. Quality indicators for colonoscopy. Am J Gastroenterol. 2006;101:873-885. [pmid: 16635231].
244 Luebke T, Baldus SE, Holscher AH, Monig SP. Splenic rupture: an unusual complication of colonoscopy: case report and review of the literature. Surgical Laparoscopy, Endoscopy & Percutaneous Techniques. 2006;16(5):351-4.
245 Shah PR, Raman S, Haray PN. Splenic rupture following colonoscopy: rare in the UK?. Surgeon Journal of the Royal Colleges of Surgeons of Edinburgh & Ireland. 2005;3(4):293-5. [pmid: 16121778].
246 Tsoraides SS, Gupta SK, Estes NC. Splenic rupture after colonoscopy: case report and literature review. J Trauma. 2007;62:255-257. [pmid: 17215767].
247 Boenicke L, Maier M, Merger M, et al. Retroperitoneal gas gangrene after colonoscopic polypectomy without bowel perforation in an otherwise healthy individual: report of a case. Langenbecks Arch Surg. 2006;391:157-160. [pmid: 16465554].
248 Gladman MA, Shami SK. Medical mystery: an unusual complication of colonoscopy—the answer. N Engl J Med. 2007;357:2309-2310. [pmid: 18046038].
249 Lambert A, Nguyen SQ, Byrn JC, Fishman EW, Shen HY. Small-bowel perforation after colonoscopy. Gastrointestinal Endoscopy. 2007;65(2):352-3. [pmid: 17137862].
250 Ladas SD, Karamanolis G, Ben-Soussan E. Colonic gas explosion during therapeutic colonoscopy with electrocautery. World Journal of Gastroenterology. 2007;13:5295-5298. [pmid: 17879396].
251 Srivastava V, Pink J, Swarnkar K, Feroz A, Stephenson BM. Colonoscopically induced appendicitis. Colorectal Dis. 2004;6:124-125. [pmid: 15008912].
252 Colonoscopes may spread HCV and HPV. AIDS Patient Care & Stds. 2003;17:257–258.
253 Fukunaga K, Khatibi A. Glutaraldehyde colitis: a complication of screening flexible sigmoidoscopy in the primary care setting. Annals of Internal Medicine. 2000;133(4):315. [pmid: 10929189].
254 Lieberman DA, Weiss DG. Veterans Affairs Cooperative Study Group. One-time screening for colorectal cancer with combined fecal occult-blood testing and examination of the distal colon. New England Journal of Medicine. 2001;345(8):555-60. [pmid: 11529208].
255 Levin TR, Farraye FA, Schoen RE, et al. Quality in the technical performance of screening flexible sigmoidoscopy: recommendations of an international multi-society task group. Gut. 2005;54:807-813. [pmid: 15888789].
256 Ramakrishnan K, Scheid DC. Selecting patients for flexible sigmoidoscopy. Determinants of incomplete depth of insertion. Cancer. 2005;103(6):1179-85. [pmid: 15674852].
257 Farraye FA, Wallace M. Clinical significance of small polyps found during screening with flexible sigmoidoscopy. Gastrointestinal Endoscopy Clinics of North America. 2002;12(1):41-51. [pmid: 11916160].
258 Atkin W, Rogers P, Cardwell C, et al. Wide variation in adenoma detection rates at screening flexible sigmoidoscopy. Gastroenterology. 2004;126(5):1247-56. [pmid: 15131784].
259 Marin Gabriel JC, Rodriguez MS, de la Cruz BJ, et al. Electrolytic disturbances and colonoscopy: bowel lavage solutions, age and procedure. Revista Espanola de Enfermedades Digestivas. 2003;95(12):863-75. [pmid: 14972007].
260 Tan JJ, Tjandra JJ. Which is the optimal bowel preparation for colonoscopy - a meta-analysis. Colorectal Disease. 2006;8(4):247-58. [pmid: 16630226].
261 Hookey LC, Depew WT, Vanner SJ. Combined low volume polyethylene glycol solution plus stimulant laxatives versus standard volume polyethylene glycol solution: a prospective, randomized study of colon cleansing before colonoscopy. Canadian Journal of Gastroenterology. 2006;101–5.
262 Sanaka MR, Super DM, Mullen KD, Ferguson DR, McCullough AJ. Use of tegaserod along with polyethylene glycol electrolyte solution for colonoscopy bowel preparation: a prospective, randomized, double-blind, placebo-controlled study. Alimentary Pharmacology & Therapeutics. 2006;23(5):669-74. [pmid: 16480406].
263 Mathus-Vliegen EM, Kemble UM. A prospective randomized blinded comparison of sodium phosphate and polyethylene glycol-electrolyte solution for safe bowel cleansing. Alimentary Pharmacology & Therapeutics. 2006;23:543-552. [pmid: 16441475].
264 Hookey LC, Depew WT, Vanner S. The safety profile of oral sodium phosphate for colonic cleansing before colonoscopy in adults. Gastrointest Endosc. 2002;56:895-902. [pmid: 12447305].
265 Johanson JF, Popp JW Jr, Cohen LB, et al. A randomized, multicenter study comparing the safety and efficacy of sodium phosphate tablets with 2L polyethylene glycol solution plus bisacodyl tablets for colon cleansing. Am J Gastroenterol. 2007;102:2238-2246. [pmid: 17573796].
266 Wruble L, Demicco M, Medoff J, et al. Residue-free sodium phosphate tablets (OsmoPrep) versus Visicol for colon cleansing: a randomized, investigator-blinded trial. Gastrointest Endosc. 2007;65:660-670. [pmid: 17173912].
267 Rex DK, Schwartz H, Goldstein M, et al. Safety and colon-cleansing efficacy of a new residue-free formulation of sodium phosphate tablets. American Journal of Gastroenterology. 2006;101(11):2594-604. [pmid: 17029618].
268 Belsey J, Epstein O, Heresbach D. Systematic review: oral bowel preparation for colonoscopy. Alimentary Pharmacology & Therapeutics. 2007;25(4):373-84. [pmid: 17269992].
269 Gonlusen G, Akgun H, Ertan A, Olivero J, Truong LD. Renal failure and nephrocalcinosis associated with oral sodium phosphate bowel cleansing: clinical patterns and renal biopsy findings. Archives of Pathology & Laboratory Medicine. 2006;130(1):101-6. [pmid: 16390223].
270 Carl DE, Sica DA. Acute phosphate nephropathy following colonoscopy preparation. Am J Med Sci. 2007;334:151-154. [pmid: 17873526].
271 Nagler J, Poppers D, Turetz M. Severe hyponatremia and seizure following a polyethylene glycol-based bowel preparation for colonoscopy. Journal of Clinical Gastroenterology. 2006;40(6):558-9. [pmid: 16825941].
272 Wu XC, Chen VW, Steele B, et al. Subsite-specific incidence rate and stage of disease in colorectal cancer by race, gender, and age group in the United States, 1992-1997. Cancer. 2001;92:2547-2554. [pmid: 11745188].
273 Thornton JG, Morris AM, Thornton JD, Flowers CR, McCashland TM. Racial variation in colorectal polyp and tumor location. Journal of the National Medical Association. 2007;99(7):723-8. [pmid: 17668638].
274 Mostafa G, Matthews BD, Norton HJ, Kercher KW, Sing RF, Heniford BT. Influence of demographics on colorectal cancer. Am Surg. 2004;70:259-264. [pmid: 15055851].
275 Nelson RL, Dollear T, Freels S, Persky V. The relation of age, race, and gender to the subsite location of colorectal carcinoma. Cancer. 1997;80:193-197. [pmid: 9217029].
276 Theuer CP, Taylor TH, Brewster WR, Campbell BS, Becerra JC, nton-Culver H. The topography of colorectal cancer varies by race/ethnicity and affects the utility of flexible sigmoidoscopy. Am Surg. 2001;67:1157-1161. [pmid: 11768820].
277 Agrawal S, Bhupinderjit A, Bhutani MS, et al. Colorectal cancer in African Americans. Am J Gastroenterol. 2005;100:515-523. [pmid: 15743345].
278 Shavers VL. Racial/ethnic variation in the anatomic subsite location of in situ and invasive cancers of the colon. Journal of the National Medical Association. 2007;99(7):733-48. [pmid: 17668639].
279 Eloubeidi MA, Wallace MB, Desmond R, Farraye FA. Female gender and other factors predictive of a limited screening flexible sigmoidoscopy examination for colorectal cancer. Am J Gastroenterol. 2003;98:1634-1639. [pmid: 12873591].
280 Schoen RE, Weissfeld JL, Bowen NJ, Switzer G, Baum A. Patient satisfaction with screening flexible sigmoidoscopy. Archives of Internal Medicine. 2000;160(12):1790-6. [pmid: 10871972].
281 Chutkan R. Colonoscopy issues related to women. Gastrointestinal Endoscopy Clinics of North America. 2006;16(1):153-63. [pmid: 16546030].
282 Lee SK, Kim TI, Shin SJ, Kim BC, Kim WH. Impact of prior abdominal or pelvic surgery on colonoscopy outcomes. Journal of Clinical Gastroenterology. 2006;40(8):711-6. [pmid: 16940884].
283 Farraye FA, Horton K, Hersey H, Trnka Y, Heeren T, Provenzale D. Screening flexible sigmoidoscopy using an upper endoscope is better tolerated by women. Am J Gastroenterol. 2004;99:1074-1080. [pmid: 15180728].
284 Lin O, Roy P, Schembre DB, Kozarek RA. Screening sigmoidoscopy and colonoscopy for reducing colorectal cancer mortality in asymtomatic persons. Cochrane Database of Systematic Reviews. 2006.
285 Gross CP, McAvay GJ, Krumholz HM, Paltiel AD, Bhasin D, Tinetti ME. The effect of age and chronic illness on life expectancy after a diagnosis of colorectal cancer: implications for screening. Ann Intern Med. 2006;145:646-653. [pmid: 17088577].
286 Walter LC, Lewis CL, Barton MB. Screening for colorectal, breast, and cervical cancer in the elderly: a review of the evidence. American Journal of Medicine. 2005;118(10):1078-86. [pmid: 16194635].
287 Lieberman D. Race, gender, and colorectal cancer screening. Am J Gastroenterol. 2005;100:2756-2758. [pmid: 16393231].
288 Cooper GS, Chak A, Koroukian S. The polyp detection rate of colonoscopy: a national study of Medicare beneficiaries. Am J Med. 2005;118:1413. [pmid: 16378787].
289 Yamaji Y, Mitsushima T, Yoshida H, et al. The malignant potential of freshly developed colorectal polyps according to age. Cancer Epidemiol Biomarkers Prev. 2006;15:2418-2421. [pmid: 17164364].
290 Centers for Disease Control and Prevention (CDC). Cancer Screening. Available at: http://www.thecommunityguide.org/cancer/screening/default.htm. Accessed 5-1-2008
291 Johnson KT, Carston MJ, Wentz RJ, Manduca A, Anderson SM, Johnson CD. Development of a cathartic-free colorectal cancer screening test using virtual colonoscopy: a feasibility study. AJR American Journal of Roentgenology. 2007;188(1):W29-36. [pmid: 17179324].
292 Taylor SA, Halligan S, Burling D, et al. Computer-assisted reader software versus expert reviewers for polyp detection on CT colonography. AJR American Journal of Roentgenology. 2006;186(3):696-702. [pmid: 16498097].
293 Dehmeshki J, Halligan S, Taylor SA, et al. Computer assisted detection software for CT colonography: effect of sphericity filter on performance characteristics for patients with and without fecal tagging. European Radiology. 2007;17(3):662-8. [pmid: 17021701].
294 van Gelder RE, Florie J, Nio CY et al. A comparison of primary two- and three-dimensional methods to review CT colonography. Eur Radiol. 2006.
295 Nio CY, de Vries AH, Stoker J. Perceptive errors in CT colonography. Abdom Imaging. 2007;32(5):556-570. [pmid: 17160495].
296 Lauenstein TC. MR colonography: current status. European Radiology. 2006;16(7):1519-26. [pmid: 16770654].
297 Saar B, Meining A, Beer A, et al. Prospective study on bright lumen magnetic resonance colonography in comparison with conventional colonoscopy. British Journal of Radiology. 2007;80(952):235-41. [pmid: 17329681].
298 Hartmann D, Bassler B, Schilling D, et al. Colorectal polyps: detection with dark-lumen MR colonography versus conventional colonoscopy. Radiology. 2006;238:143-149. [pmid: 16304088].
299 Haykir R, Karakose S, Karabacakoglu A, Kayacetin E, Sahin M. Detection of colonic masses with MR colonography. Turk J Gastroenterol. 2006;17:191-197. [pmid: 16941252].
300 Haykir R, Karakose S, Karabacakoglu A, Sahin M, Kayacetin E. Three-dimensional MR and axial CT colonography versus conventional colonoscopy for detection of colon pathologies. World Journal of Gastroenterology. 2006;12:2345-2350. [pmid: 16688823].
301 Lam WW, Leung WK, Wu JK, So NM, Sung JJ. Review article: balancing the ideal versus the practical-considerations of colorectal cancer prevention and screening. Journal of Magnetic Resonance Imaging. 2004;447–452.
302 Ajaj W, Pelster G, Treichel U, et al. Dark lumen magnetic resonance colonography: comparison with conventional colonoscopy for the detection of colorectal pathology. Gut. 2003;52:1738-1743. [pmid: 14633953].
303 Luboldt W, Bauerfeind P, Wildermuth S, Marincek B, Fried M, Debatin JF. Colonic masses: detection with MR colonography. Radiology. 2000;216:383-388. [pmid: 10924558].
304 Pappalardo G, Polettini E, Frattaroli FM, et al. Magnetic resonance colonography versus conventional colonoscopy for the detection of colonic endoluminal lesions. Gastroenterology. 2000;119(2):300-4. [pmid: 10930364].
305 Kanaoka S, Yoshida K, Miura N, Sugimura H, Kajimura M. Potential usefulness of detecting cyclooxygenase 2 messenger RNA in feces for colorectal cancer screening. Gastroenterology. 2004;127:422-427. [pmid: 15300574].
306 Jin YM, Li BJ, Qu B, Du YJ. BRAF, K-ras and BAT26 mutations in colorectal polyps and stool. World Journal of Gastroenterology. 2006;12:5148-5152. [pmid: 16937524].
307 Brenner DE, Rennert G. Fecal DNA biomarkers for the detection of colorectal neoplasia: attractive, but is it feasible?. J Natl Cancer Inst. 2005;97:1107-1109. [pmid: 16077063].
308 Woodson K, Weisenberger DJ, Campan M, et al. Gene-specific methylation and subsequent risk of colorectal adenomas among participants of the polyp prevention trial. Cancer Epidemiol Biomarkers Prev. 2005;14:1219-1223. [pmid: 15894675].
309 Kato S, Fu KI, Sano Y, et al. Magnifying colonoscopy as a non-biopsy technique for differential diagnosis of non-neoplastic and neoplastic lesions. World Journal of Gastroenterology. 2006;12:1416-1420. [pmid: 16552812].
310 Togashi K, Hewett DG, Whitaker DA, Hume GE, Francis L, Appleyard MN. The use of acetic acid in magnification chromocolonoscopy for pit pattern analysis of small polyps. Endoscopy. 2006;38:613-616. [pmid: 16612744].
311 Hurlstone DP, Cross SS, Adam I, et al. Efficacy of high magnification chromoscopic colonoscopy for the diagnosis of neoplasia in flat and depressed lesions of the colorectum: a prospective analysis.[see comment]. Gut. 2004;53:284-290. [pmid: 14724165].
312 Seike K, Koda K, Oda K, et al. Assessment of rectal aberrant crypt foci by standard chromoscopy and its predictive value for colonic advanced neoplasms. Am J Gastroenterol. 2006;101:1362-1369. [pmid: 16771962].
313 Fu KI, Sano Y, Kato S, et al. Chromoendoscopy using indigo carmine dye spraying with magnifying observation is the most reliable method for differential diagnosis between non-neoplastic and neoplastic colorectal lesions: a prospective study. Endoscopy. 2004;36:1089-1093. [pmid: 15578300].
314 Eisen GM, Kim CY, Fleischer DE, et al. High-resolution chromoendoscopy for classifying colonic polyps: a multicenter study. Gastrointest Endosc. 2002;55:687-694. [pmid: 11979251].
315 Hurlstone DP, Sanders DS. Recent advances in chromoscopic colonoscopy and endomicroscopy. Current Gastroenterology Reports. 2006;8(5):409-15. [pmid: 16968609].
316 Taylor JC, Kendall CA, Stone N, Cook TA. Optical adjuncts for enhanced colonoscopic diagnosis. British Journal of Surgery. 2007;94(1):6-16. [pmid: 17205497].
317 Dhar A, Johnson KS, Novelli MR, et al. Elastic scattering spectroscopy for the diagnosis of colonic lesions: initial results of a novel optical biopsy technique. Gastrointest Endosc. 2006;63:257-261. [pmid: 16427931].
318 Eliakim R, Fireman Z, Gralnek IM, et al. Evaluation of the PillCam Colon capsule in the detection of colonic pathology: results of the first multicenter, prospective, comparative study. Endoscopy. 2006;38(10):963-70. [pmid: 17058158].
319 Arber N, Grinshpon R, Pfeffer J, Maor L, Bar-Meir S, Rex D. Proof-of-concept study of the Aer-O-Scope omnidirectional colonoscopic viewing system in ex vivo and in vivo porcine models. Endoscopy. 2007;39(5):412-7. [pmid: 17516347].
320 Vucelic B, Rex D, Pulanic R, et al. The aer-o-scope: proof of concept of a pneumatic, skill-independent, self-propelling, self-navigating colonoscope. Gastroenterology. 2006;130(3):672-7. [pmid: 16530508].
321 Pfeffer J, Grinshpon R, Rex D, et al. The Aer-O-Scope: proof of the concept of a pneumatic, skill-independent, self-propelling, self-navigating colonoscope in a pig model. Endoscopy. 2006;38:144-148. [pmid: 16479421].
322 Winawer SJ, Zauber AG. Colonoscopic polypectomy and the incidence of colorectal cancer. Gut. 2001;48:753-754. [pmid: 11358886].
323 Hughes K, Leggett B, Del Mar C, et al. Guaiac versus immunochemical tests: faecal occult blood test screening for colorectal cancer in a rural community. Australian & New Zealand Journal of Public Health. 2005;29(4):358-64. [pmid: 16222934].
324 Federici A, Giorgi RP, Borgia P, Bartolozzi F, Farchi S, Gausticchi G. The immunochemical faecal occult blood test leads to higher compliance than the guaiac for colorectal cancer screening programmes: a cluster randomized controlled trial. J Med Screen. 2005;12:83-88. [pmid: 15949119].
325 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. New England Journal of Medicine. 2000;343(22):1603-7. [pmid: 11096167].
326 Towler B, Irwig L, Glasziou P, Kewenter J, Weller D, Silagy C. A systematic review of the effects of screening for colorectal cancer using the faecal occult blood test, Hemoccult. BMJ. 1998;317:559-565. [pmid: 9721111].
327 Levi Z, Chorev N, Segal N, et al. Screening for colorectal cancer in personnel of an academic medical center. Digestive Diseases & Sciences. 2007;52(9):2301-4. [pmid: 17385033].
328 Whiting P, Rutjes AW, Reitsma JB, Glas AS, Bossuyt PM, Kleijnen J. Sources of variation and bias in studies of diagnostic accuracy: a systematic review. Ann Intern Med. 2004;140:189-202. [pmid: 14757617].
329 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. 2003;3:25. [pmid: 14606960].
330 O'Brien K, Sweeney BF Jr, Conger N, Fischer JR, Lang KA. Prevalence of proximal adenomas after an adenoma is found on flexible sigmoidoscopy. Cancer Detection & Prevention. 2003;27(4):259-65. [pmid: 12893073].
331 Imperiale TF, Glowinski EA, Lin-Cooper C, Larkin GN, Rogge JD, Ransohoff DF. Five-Year Risk of Colorectal Neoplasia after Negative Screening Colonoscopy. N Engl J Med. 2008;359:1218-1223. [pmid: 18799558].
332 Lieberman DA, Weiss DG, Harford WV, et al. Five-year colon surveillance after screening colonoscopy. Gastroenterology. 2007;133:1077-1085. [pmid: 17698067].
333 Rex DK, Cummings OW, Helper DJ, et al. 5-year incidence of adenomas after negative colonoscopy in asymptomatic average-risk persons [see comment]. Gastroenterology. 1996;111:1178-1181. [pmid: 8898630].
334 Hosokawa O, Shirasaki S, Kaizaki Y, Hayashi H, Douden K, Hattori M. Invasive colorectal cancer detected up to 3 years after a colonoscopy negative for cancer. Endoscopy. 2003;35:506-510. [pmid: 12783349].
335 Neugut AI, Jacobson JS, Ahsan H, et al. Incidence and recurrence rates of colorectal adenomas: a prospective study. Gastroenterology. 1995;108:402-408. [pmid: 7835580].
336 Avidan B, Sonnenberg A, Schnell TG, Leya J, Metz A, Sontag SJ. New occurrence and recurrence of neoplasms within 5 years of a screening colonoscopy. American Journal of Gastroenterology. 2002;97(6):1524-9. [pmid: 12094877].
337 Sawhney MS, Farrar WD, Gudiseva S, et al. Microsatellite instability in interval colon cancers. Gastroenterology. 2006;131(6):1700-5. [pmid: 17087932].
338 Rex DK, Rahmani EY, Haseman JH, Lemmel GT, Kaster S, Buckley JS. Relative sensitivity of colonoscopy and barium enema for detection of colorectal cancer in clinical practice. Gastroenterology. 1997;112:17-23. [pmid: 8978337].
339 Farrar WD, Sawhney MS, Nelson DB, Lederle FA, Bond JH. Colorectal cancers found after a complete colonoscopy. Clinical Gastroenterology & Hepatology. 2006;4(10):1259-64. [pmid: 16996804].
340 Morikawa T, Kato J, Yamaji Y, et al. Sensitivity of immunochemical fecal occult blood test to small colorectal adenomas. Am J Gastroenterol. 2007;102:2259-2264. [pmid: 17617203].
341 Pickhardt PJ, Hanson ME, Vanness DJ, et al. Unsuspected extracolonic findings at screening CT colonography: clinical and economic impact. Radiology. 2008;249:151-159. [pmid: 18796673].
342 Pickhardt PJ, Kim DH, Taylor AJ, Gopal DV, Weber SM, Heise CP. Extracolonic tumors of the gastrointestinal tract detected incidentally at screening CT colonography. Dis Colon Rectum. 2007;50:56-63. [pmid: 17115333].
343 Gluecker TM, Johnson CD, Wilson LA, et al. Extracolonic findings at CT colonography: evaluation of prevalence and cost in a screening population. Gastroenterology. 2003;124:911-916. [pmid: 12671887].
344 Ginnerup PB, Rosenkilde M, Christiansen TE, Laurberg S. Extracolonic findings at computed tomography colonography are a challenge. Gut. 2003;52:1744-1747. [pmid: 14633954].
345 Hara AK, Johnson CD, MacCarty RL, Welch TJ. Incidental extracolonic findings at CT colonography. Radiology. 2000;215:353-357. [pmid: 10796907].