# Discussion

Research substantiating the mortality benefit of various CRC screening approaches is not significantly different from the evidence base for the 2002 USPSTF recommendation. There are still no screening trials reporting mortality outcomes for any screening methods except guaiac FOBT screening using Hemoccult or Hemoccult II. At the time of this report, results from a number of trials or studies of CRC screening methods are pending (see Ongoing Studies section and Appendix G), including four trials of FS addressing health and mortality outcomes. While two of these FS trials appear to be completed, ^81,^ ^202^ contact with investigators confirmed that their results are still unavailable.

A substantial body of research on other aspects of CRC screening has been published since the 2002 recommendation, and this remains a very active area of international research. We have organized the discussion of our findings by screening test, rather than by key question, to allow a synthesized consideration of the evidence on potential CRC screening test options. A summary of the overall evidence is provided in Table 9.

Table 9 Summary evidence table

No. of studies | Design | Limitations | Consistency | Applicability | Overall Internal Validity | Summary of Findings | Comment
KQ1. What is the effectiveness of CRC screening methods (alone or in combination) in reducing mortality from colorectal cancer?
1 meta-analysis 4 RCTs | Meta-analysis and RCTs | New CRC mortality reports from screening trials only address longer-term follow up of standard guaiac FOBT screening programs. | CRC mortality reduction estimates from biennial FOBT screening RCTs are reasonably consistent; in one trial, inclusion of CRC-related treatment deaths reduces mortality benefit to 11% which is no longer statistically significant. | Population screening trials conducted in US, UK, Sweden, and Denmark in ages 45 to 80 years. NonWhite populations not well represented in these countries. | Good | CRC, but not all-cause, mortality is reduced 13–21% (pooled estimate: RR 0.85; CI: 0.78, 0.92), generally after 8 to 13 years in biennial FOBT screening programs. Higher mortality reductions have been seen in the single annual screening trial (33%), but this trial also had higher participation rates through enlisting only volunteers. Initial participation after mailed invitation to the FOBT screening programs is high (60 to 67%) and overall participation in screening rounds is 30 to 60%. CRC incidence may be reduced with FOBT screening programs, but not until 3 to 5 years after screening programs cease. | Four FS RCTs (PLCO, SCORE, UK Flex Sig, NORCCAPS) are completed (but not published) or still underway. These trials test FS using protocols for colonoscopy referral with and without biopsy. These trials will report CRC mortality endpoints.
KQ2a. What are the sensitivity and specificity of colonoscopy and flexible sigmoidoscopy when used to screen for CRC in the community practice setting?
Colonoscopy
3 studies of test accuracy for colonoscopy compared with CTC; “enhanced” reference standard of second-look colonoscopy for discrepancies between CTC and colonoscopy | Cross-sectional cohort | Small number of patients studied (1781 total). Number of colonoscopists varied between studies, from five to 50, which complicates test accuracy estimates with considerations of training and experience. Estimates of colonoscopy test performance are hampered by lack of a true gold standard. | Consistent estimates are hampered by variability in CT technology (e.g., use of contrast agent vs. no contrast agent, 2D vs. 3D). All studies conducted in average-risk screening populations. | Estimates are not precise or clearly applicable to the community endoscopists. | Fair | Sensitivity of colonoscopy for CRC varied widely (20 percent to 50 percent) due in part to small numbers of cancers (7 total CRCs detected in all 3 studies). Sensitivity for large adenomas (10 mm or larger) ranged from 77 percent to 100 percent. Sensitivity for smaller polyps is harder to estimate due to inconsistent reporting, but suggests about a 10 percent miss rate. | These data are mostly useful to support the need for performance standards for community colonoscopy, particularly for screening.
Flexible sigmoidoscopy
3 cohort studies of FS examinations 6 cohort studies of screening colonoscopies | 2 prospective cohort studies 7 cross-sectional cohort studies | Using screening colonoscopy to estimate FS results likely overestimates sensitivity because studies considered all neoplasia distal to the splenic flexure as detected by FS, but the colonoscopy bowel preparation is superior to that for FS. Endoscopist skill for colonoscopy may also vary from FS. | Six screening colonoscopy studies (n=14,938) supply data to simulate one FS screening protocol of biopsy & colonoscopy referral for adenomas of any size; Two of these screening colonoscopy studies (n=6,146) also simulate the FS screening protocol of colonoscopic referral for any lesion visualized with no biopsy done. | Estimates are taken from studies conducted in average risk screening populations. | Fair | In 3982 average-risk adults, the sensitivity of simulated FS with biopsy for CRC throughout the colon ranged from 58.3 to 62.5 percent. Among 14,938 predominantly average risk adults aged 40–79 years, estimated sensitivity of FS with biopsy for advanced neoplasia throughout the colon ranged from 70 to 86% (excluding an outlier of 50 percent in women examined in military medical centers). The sensitivity of simulated FS without biopsy for CRC was 75%, based on a single study (n =1994), and ranged from 77 to 86% for advanced neoplasia (n = 6146). Among persons with no distal adenomas on FS, isolated advanced proximal neoplasia occurred in 0.8 to 3.2%, giving a best-case estimate of the false negative rate for FS. | Simulated estimates of FS test performance characteristics with and without biopsy should be unnecessary once results are reported from four pending RCTs.
KQ2b. What are the test performance characteristics of CT-assisted colonography and fecal screening tests (e.g., high-sensitivity guaiac fecal occult blood testing (FOBT), fecal immunochemical test, or fecal DNA tests) for CRC screening as compared to an acceptable reference standard?
CT colonography (CTC)
3 studies of test accuracy (supplemented by two studies re-examining the findings from the largest study) | Cross-sectional cohort studies | Differences in CTC technology and variability between readers limit studies' ability to provide precise estimates of CTC performance, particularly for lesions smaller than 10 mm in size. Health implications of uncertainties in test performance are unclear. | One large study (n=1233) using 3D flythrough endoluminal imaging represents most (69%) of patients studied, and is the only one to use contrast to allow fecal tagging and endoluminal fluid opacification. Two smaller studies (n=96 and n=452) compare 3D virtual dissection with 2D imaging. | The best data come from a single study using CT technologies and experienced readers whose generalizability to community CTC practices must be considered. Superiority of 3D compared with 2D techniques is not clear. Reader variability remains a factor. | Fair to Good | Among 1233 average risk patients, per-patient sensitivity of 3D endoluminal CTC was 93.8% for large (greater than 10 mm) adenomas and 88.7% for adenomas 6 mm or larger; sensitivity estimates were not statistically significantly different based on polyp size nor from sensitivity estimates for optical colonoscopy (OC). Specificity was significantly lower for lesions 6 mm or larger (79.6%) than for lesions 8 mm (92.2%) or 10 mm (96%) in size or larger. In two other studies (n=548) sensitivity and specificity of virtual dissection 3D CTC ranged from 73 to 100% (sensitivity) and 98 to 100% (specificity) for lesions 10 mm or greater and 60 to 75% (sensitivity) and 89 to 99% (specificity) for lesions 6 mm or greater. 3D sensitivity and specificity estimates were not clearly different from estimates for 2D imaging. Our best estimate is that between one in three and one in twelve patients would be referred for OC after CTC screening. | Reported but as-yet- unpublished results from the multisite National CT colonography trial (ACRIN) come from 15 US centers who evaluated CTC using primary 2D or 3D readings in 2531 asymptomatic persons. Reported but unpublished results from the Munich CRC Prevention trial (300 average-risk patients) also suggest excellent per-patient sensitivity for polyps of all sizes, but do not report specificity. Inconsitencies and incompleteness of presented but not published data could soon be resolved.
Fecal tests
High-sensitivity guaiac: 2 studies of test accuracy Fecal Immunochemical Test (FIT): 9 studies of test accuracy Fecal DNA: 2 studies of test accuracy 11 total studies as 2 studies evaluated both FIT and high-sensitivity guaiac) | 5 prospective cohort 6 cross-sectional cohort | High-sensitivity guaiac: Two comparative studies, one using different reference standards for different tests. FIT: FITs cannot be compared as a class and there are many different tests, with few studies per test. Performance for all but one FIT was reported qualitatively at a single cut-point rather than quantitatively (i.e., across multiple cut-points). Several studies used registry followup for screen-negative patients, likely overestimating sensitivity. Fecal DNA: One study for each of two approaches. Only Fecal DNA panel had any sensitivity for CRC and it has been replaced by upgraded tests. | High-sensitivity guaiac: One study provides estimates for left-sided cancers only. FIT: Estimates of sensitivity and specificity did show variability within each test. This may be due in part to different collection methods and reference standard applied. Fecal DNA: NA | Most FIT studies evaluated non- FDA approved tests (or those not on the US market). No eligible studies were found for most FDA-approved FIT tests (e.g., Insure/Inform, Quickvue, Hemosure) Fecal DNA panel was tested in a subgroup (n = 2507) with CRC, advanced adenomas or tumors (n = 436), and a randomly selected group with minor (n = 648) or no (n = 1423) detected polyps. Population was older (75% > 65 y) than usual CRC screening population; panel test evaluated has been replaced and now requires premarket review by FDA. | High-sensitivity guaiac: Fair FIT: Fair Fecal DNA: Fair to Poor | High-sensitivity guaiac: In one comparative cohort study in 8104 average-risk sceening patients, Hemoccult Sensa (13.6% test positives) was more sensitive for CRC (79.4%) than Hemoccult II (37.1%), but with lower specificity (86.7% vs 97.7%). A second study (n=5841) of left-sided CRC found Hemoccult Sensa positive in 10.1% with a sensitivity of 64.3% and specificity of 90.1%. FIT: Studies with a total of 86,498 average-risk patients were located that provided estimates for Magstream (and related tests), OC-Hemodia, FlexSure OBT (now Hemoccult ICT), and Monohaem. Across the tests, sensitivity for CRC ranged from 61% to 88% with specificity ranging from 91–98%. Test positive rates were generally between 2.0% and 5.9%. Fecal DNA: For PreGenPlus^TM^ fecal DNA panel, sensitivity for CRC was 51.6% with a specificity of 94.4%. Test positives were 8.2%. In comparison, Hemoccult II sensitivity for CRC was 12.9% and specificity was 94.3%, with 5.8% test positives. Among all participants (n = 5486), more (11.7%) did not adhere to fecal DNA tests than to Hemoccult II (7.8%). | Sensitivity of non-rehydrated Hemoccult II for CRC ranged from 25 to 38 percent (with one outlier study of 60 percent) and specificity was 98–99 percent in a recent systematic review. Results are pending from NCT00025025 (Colorectal Cancer Screening: Fecal Blood vs. DNA. David Ahlquist MD, Mayo Clinic Cancer Center, protocol chair). A randomized multicenter study of 2000 patients (65–80 years of age) undergoing FOB testing, a newer generation multi-target DNA-based panel testing of blood and of stool, and colonoscopy.
KQ3a. What are the age-specific rates of harm from colonoscopy and flexible sigmoidoscopy in the community practice setting?
Colonoscopy
16 cohort studies | 3 retrospective cohort; 13 prospective cohort (6 nested within trials) | Not all studies were conducted in a community setting. However those conducted in research or academic settings were conducted in asymptomatic populations. Variation in duration of followup and methods for determining adverse events. | No significant statistical heterogeneity in pooling estimates of serious adverse events. Limited meta-regression showed that only study setting by country was significantly associated with complications from perforations. However, stratified analyses by country of setting did not produce clinically significantly different estimates harms (total, perforation, bleeding). | All studies conducted either among asymptomatic persons or in a community setting, or both. | Fair | In 11 studies (n=55,211), serious complications occurred in 3.1 per 1000 procedures (CI: 1.7, 5.8). In the six US studies, serious complications occurred in 2.9 per 1000 procedures (CI: 1.2, 7.6). In 13 studies (n=173,391), perforations occurred in 5.6 per 10,000 procedures (CI: 2.2, 14.5). In the eight US studies, perforations occurred in 3.8 per 10,000 procedures (CI: 1.4, 10.4). In 12 studies (n=55,461), major bleeding occurred in 12 per 10,000 procedures (CI: 8.9, 16). In the seven US studies, major bleeding occurred in 12.3 per 10,000 procedures (CI: 7.8, 19.3). Unable to obtain reliable pooled estimates for the proportion of other types of complications, including death, due to sparse data. | Only one study (Newcomer 1999) was included in the 2002 review. One study (Ko 2007) is currently only available in abstract form, additional details were provided by the author.
Flexible sigmoidoscopy
8 cohort studies | 2 retrospective cohort 6 prospective cohort (2 nested within trials) | Five studies not conducted in the US and endoscopist characteristics not reported in 3 of the 5 studies. Variation in duration of followup and methods for determining adverse events. | No significant statistical heterogeneity in pooling estimates of serious adverse events. Limited meta-regression showed that only study setting by country was significantly associated with total serious complications. However, stratified analyses by country of setting did not produce clinically significantly different estimates harms. | All studies conducted among asymptomatic, average-risk persons. | Fair | In 6 studies (n=126,985), serious complications occurred in 3.4 per 10,000 procedures (CI: 0.6,19). In the two US studies, serious complications occurred in 0.9 per 10,000 procedures (CI: 2 per million, 50 per 10,000). In 7 studies (n=134,119), perforations occurred in 4.6 per 100,000 procedures (CI: 0.4, 59). In the three US studies, perforations occurred in 0.2 per 10,000 procedures (CI: 1 per million, 3.5 per 10,000). Unable to obtain reliable pooled estimates for the proportion of other types of complications due to sparse data. | Only one study (Atkin 1998) was included in the 2002 review.
KQ 3b. What are the adverse effects of CT colonography (CTC) and/or fecal screening tests (high-sensitivity fecal occult blood tests, fecal immunochemical, and fecal DNA)?
CT colonography (CTC)
5 cohort studies | 3 prospective cohort 2 retrospective cohort | Unclear clinical significance of perforations visualized on CT. No direct evidence of harms from low-dose ionizing radiation from CT studies. | Three prospective studies included predominantly asymptomatic, average- risk populations. Two large retrospective studies included both symptomatic and asymptomatic persons. Risk of perforations from CTC appears higher in symptomatic persons. | Evidence for harms from CTC among asymptomatic persons not in community settings | Fair | In 3 prospective studies (n=4707) and the asymptomatic subgroup of one large retrospective study (n=11,707), there were no serious complications, including perforation. In the other large retrospective study (n=11,870), with both symptomatic and asymptomatic patients, there were 7 total perforations. However, only one perforation occurred in the asymptomatic population (the number of screening CTC procedures is not reported). | One study (Pickhardt 2006) is only available in abstract form, additional details were provided by the author. Indirect evidence of risk of malignancy from low-dose ionizing radiation is included in the discussion.
Fecal tests
No studies

## CRC Screening using FOBT and other Fecal Screening Tests

### Guaiac FOBT screening programs

CRC mortality reductions due to FOBT screening reported in the previous review were generally maintained through longer-term followup. We found new reports of longer-term followup of biennial FOBT screening trials indicating CRC mortality was reduced 13 to 21 percent after 8 to 13 years of screening in two trials, although another two trials did not show mortality benefit until after 15–18 years of screening. A recent meta-analysis from the Cochrane Collaboration pooled CRC mortality reduction estimates for biennial screening at the last followup for four FOBT trials (i.e., at 11.7 years, ^132^ 15 years, ^94^ 17 years, ^131^ and 18 years ^135^ ). The overall estimate of CRC mortality reduction was 15 percent using either random- or fixed-effect models (RR 0.85, CI: 0.78,0.92). ^94^ This analysis did not incorporate recently reported data from one of these trials, suggesting that CRC mortality benefit is no longer statistically significant at 17 years when deaths due to CRC treatment are included (RR 0.89, CI: 0.78,1.01). ^131^ Since comparable data on treatment-related CRC deaths are not reported in the other trials, and very limited details about the underlying analysis are reported, this finding is difficult to interpret. And, while meta-analysis of all four FOBT screening trials indicated no benefit for all-cause mortality (RR 1.00, CI: 0.99,1.03), ^94,^ ^131,^ ^203^ CRC screening would not be expected to reduce all-cause mortality in these trials due to the relatively low contribution of CRC mortality to overall mortality and power issues affecting the precision of all-cause mortality estimates. ^204^ – ^208^ Consistent with the USPSTF methodology, data on both cause-specific as well as all-cause mortality are considered relevant. However, in valuing the impact these data have on their recommendations, the USPSTF also considers methodological issues that may impact their interpretation.

### Accuracy of newer fecal tests

Policymakers and clinicians seek evidence on test performance to guide decisions about substituting newer fecal tests for standard guaiac tests in order to improve FOBT screening programs for CRC. Screening tests that are more sensitive (but equally specific) may produce value by detecting extra cases of CRC with fecal screening without imposing a higher burden of false-positive test results (and associated risks). Methodologists suggest that, in the case of new diagnostic tests, evidence of this type of superior test accuracy provides a sufficient evidence basis for test substitution without conducting new randomized trials, if the additional cases are in patients that represent the same disease spectrum; this is likely if the reference standard is the same in the test accuracy studies as in the trials showing treatment benefit. ^209^ Based on this standard, and the use of colonoscopy in test accuracy as well as treatment trials, it is reasonable to assume that some fecal tests with improved sensitivity and similar specificity (relative to Hemoccult II) could be considered as substitutes in fecal screening programs. The best evidence to evaluate screening test performance of newer fecal tests in average-risk screening populations is available for four individual fecal immunochemical tests (FITs): Magstream/HemeSelect; FlexSure OBT/Hemoccult ICT; OC-Hemodia; and Monohaem. FITs cannot be analyzed as a class. ^123^ More limited data is available for Hemoccult Sensa, and very limited data is available for fecal DNA tests. Where test accuracy results do not indicate superior test sensitivity with comparable specificity, determining the trade-offs between sensitivity and specificity of these different fecal occult blood options, particularly in a program of repeated screening over time, requires modeling. The companion decision analysis ^11^ examines the comparative benefits and harms of Hemoccult Sensa, Hemoccult II, and FIT testing.

Fecal immunochemical tests (FIT). A large body of evidence (86,498 average-risk persons studied) from cohort studies has evaluated the screening test performance of specific FITs: OC-Hemodia, Monohaem, FlexSure OBT (now called Hemoccult ICT), Magstream, and HemeSelect (early generation, qualitative test related to Magstream). Qualitative and quantitative results from at least 2-day sampling suggest superior sensitivity for CRC of HemeSelect (68.8 percent) when directly compared with the sensitivity of concurrent nonrehydrated Hemoccult II of (37.1 percent). ^160^ The sensitivity for CRC of the other tested FITs (range: 61 percent to 88.9 percent) also exceeds that of nonrehydrated Hemoccult II (range: 25 to 38 percent, with one outlier study of 60 percent) as reported in four adequately powered cohort studies in average-risk patients in a recent systematic review. ^122^ Sensitivity for advanced neoplasia or large adenoma is less commonly reported, but ranges between 27 and 67 percent in FITs, which is at least comparable if not superior to the sensitivity for nonrehydrated Hemoccult II from a direct comparison (31 percent). ^160^ Specificity of FITs for CRC is generally lower (91 percent to 97 percent) than with nonrehydrated Hemoccult II (98 percent to 99 percent), although quantitative FITs (Magstream) using the higher cutpoint (75 ng/ml) and combination Hemoccult Sensa/FIT tests report specificity estimates comparable to nonrehydrated Hemoccult II. Almost all of these FIT studies used methods that could inflate estimates of diagnostic accuracy due to verification bias (partial or complete). ^154^ One also cannot assume that results from tested FITs are generalizable to other untested FITs. ^122^ As of this writing, only FlexSure OBT (Hemoccult ICT) appears to be currently on the US market. Magstream, the only test with quantitative results and an automated reader, has been adopted for use in the Australian national screening program. ^210^ No adequate clinical accuracy data could be located for other FDA-approved tests, including the Insure test. Insure uses a promising brush sampling technique that has been reported to significantly increase FOBT program participation in a RCT comparing guaiac testing and another FIT, both based on spatula sampling. ^211^

Hemoccult Sensa. Although this high-sensitivity guaiac test has been available for many years, no well-designed (i.e., cohort) studies have compared Hemoccult results to an adequate reference standard (e.g., colonoscopy) in all average-risk persons being screened. Another recent systematic review that comprehensively considered fecal occult blood tests for CRC screening also did not find a large body of research on Hemoccult Sensa. ^122^ These reviewers found a total of four screening accuracy studies examining Hemoccult Sensa. ^160,^ ^212^ – ^214^ We excluded two of these studies for the following reasons: 1) case-control design ^213^ (these designs exaggerate estimates of sensitivity); ^122,^ ^154^ 2) use of an inadequate reference standard for detecting both CRC and polyps, and inadequate data reporting to allow sensitivity calculations for CRC alone. ^212^ Another trial (reported in abstract) from this review is now published ^159^ and we had reviewed the fourth. ^160^ The best available evidence for Hemoccult Sensa is from two large cohort studies (n= 13,945 total) in a single managed care organization's health appraisal unit. ^159,^ ^160^ These studies compare Hemoccult Sensa with Hemoccult II and with two FITS, Hemeselect and FlexSure, which were analyzed as both primary screening tests and in combination with Hemoccult Sensa for CRC screening in average-risk adults. Hemoccult Sensa had five times the test-positivity rate as Hemoccult II and two to three times the test-positivity rate as FITs (alone or in series after a positive Hemoccult Sensa result). Although Hemoccult Sensa had significantly improved test sensitivity for CRC (79.4 percent compared with 37.1 percent for Hemoccult II), it was not more accurate than either FIT alone or combination Hemoccult Sensa/FIT testing. Of all the newer fecal tests we evaluated, limited data on Hemoccult Sensa suggested it has the lowest specificity.

Fecal DNA tests. Despite significant media attention, fecal DNA tests are still a developing technology and few have any clinical accuracy evaluations. One fair-quality cohort study evaluated average-risk patients (n=2507) using a multitarget fecal DNA panel (Pre-Gen Plus), compared with colonoscopy. Patients also received Hemoccult II. The fecal DNA panel was more sensitive (51.6 percent, CI: 34.8, 68.0) than nonrehydrated Hemoccult II (12.9 percent, CI: 5.1, 28.9) for CRC, but also had higher test positivity (8.2 percent vs. 5.8 percent). Neither test was sensitive, nor superior to the other, for detecting advanced adenomas (11 to 15 percent). Specificity for minor polyps was similarly high in both fecal tests (92.4 and 95.2 percent).

This trial has limitations that prevent it from providing strong evidence to support the current use of fecal DNA testing in CRC screening. ^215^ These limitations include questions about the study's generalizability—in light of selectively enrolling patients older than 65 years, focusing on a selected spectrum of patients and not analyzing all patients to estimate the sensitivity and specificity of this test, and excluding 20 percent of persons from the analysis—and about the its true magnitude of benefit above Hemoccult II, given the wide confidence intervals around the study's estimates of sensitivity. A major additional concern, however, is that the FDA has recently notified the manufacturer that Pre-Gen Plus (the only commercially available fecal DNA test for CRC screening) is classified as a medical device and thus requires pre-market approval before it can be legally marketed. ^216^ This factor was cited in the decision by the Center for Medicare and Medicaid Services (CMS) in its recent decision to deny coverage for fecal DNA testing in CRC screening. ^217^ Once these issues are resolved, however, decision-makers will still need to carefully consider whether there is a mismatch between the tests for which there is clinical data supporting their test performance and those that are commercially available. The fecal DNA test evaluated in the fair-quality cohort study was a pre-commercial version (1.0) that has been replaced by a new commercial version (1.1), with other versions in the pipeline. ^218^ While ongoing development aims to improve various aspects of test performance—including DNA purification, DNA stabilization in the stool, and other aspects—a mismatch between available evidence of clinical accuracy and the commercially available tests is likely to continue into the future. And, although there are pending trials (see Appendix G), these reflect different versions of the test and illustrate the rapid evolution of this developing technology. Some researchers have indicated that, even when some of the pending study results become available, the fecal DNA test version evaluated will not represent the most advanced “next generation” of fecal DNA testing. ^219^

A final consideration about fecal DNA testing relates to whether it is a substitute for FOBT testing every one or two years in a program of screening or should be used differently. The current clinical data supporting fecal DNA testing is limited to evaluating one-time testing (and not a program of testing), and there is no independent data on which to suggest a different rescreening interval than annually or biennially, as in FOBT screening programs. However, a recent modeling analysis for CMS on the cost-effectiveness of fecal DNA testing indicated that, even when fecal DNA was repeated only every three to five years, the costs would need to be substantially lower than at present for fecal DNA to be cost-effective compared with other currently recommended CRC screening strategies. ^218^

### Harms with fecal screening

We did not find any studies meeting our inclusion criteria addressing significant adverse effects of high-sensitivity guaiac FOBT, FIT, or fecal DNA tests. A recent systematic review of FOBTs and FITs found that only a few trials of FOBT have investigated the impact of being offered FOBT testing, and of positive FOBT test results, on daily life, and then only in a very small proportion of those being screened. ^122^ Some degree of worry can be engendered by being offered the test, but this worry is generally mild; sixty to seventy percent of those with a positive test may be worried about cancer (some call it severe worry, although most experience slight distress), and anxiety associated with false positive tests is highest before followup colonoscopy. In general, although concerns have been expressed, ^220^ data are quite limited to determine whether there are meaningful psychological impacts from fecal screening. However, patients with false-positive fecal test results also experience the risk of complications associated with colonoscopy. Consideration of these potential risks is warranted before substituting more sensitive FOBT or other fecal screening tests for standard guaiac FOBT that have been tested in randomized controlled trials of screening programs. If substitution gains sensitivity, but there is also an increase in false positives (due to decreased specificity), additional colonoscopies would be expected, the potential harms of which may be significant. Ultimately, the issue of considering the incremental harms and benefits will require some degree of modeling in the absence of comparative studies reporting health outcomes. The companion decision analysis should help inform these considerations. ^11^ A hypothetical harm associated with fecal DNA is posed by the potentially greater significance given to false-positive and false-negative results with DNA testing, due to public opinion/belief/bias surrounding DNA testing. ^215^

## CRC Screening Using Direct Visualization: CT Colonography (CTC), Colonoscopy, and Flexible Sigmoidoscopy (FS)

Colonoscopy and other direct visualization techniques offer significant benefits above fecal tests in allowing greater sensitivity with a single test. In addition, colonoscopy allows treatment with polypectomy, if warranted, to occur during the screening test. Concerns about the availability of resources for screening colonoscopy, the greater potential for adverse effects, and considerations of the acceptability of a program of repeated colonoscopic screenings have driven much of the continuing search for new or alternate CRC screening methods. These include visualization methods other than colonoscopy. As such, CTC is the only newer technology (among MR colonography and enhancements in colonoscopy procedures or equipment) that has progressed enough to be potentially applicable for CRC screening in average-risk adults. However, research reports on newer technologies or on enhancements to existing technologies continue to accrue, ^221^ leaving the state of the science for potential CRC screening technologies subject to ongoing, potentially rapid, change.

Along with test accuracy, harms associated with these screening approaches are important considerations. In this updated review, our objective was to quantify serious adverse events for colorectal cancer screening. To evaluate harms, we included only studies with largely asymptomatic populations, usually an average-risk population, or studies conducted in a community setting. Therefore, only one study using flexible sigmoidoscopy and one study using colonoscopy ^180^ from the prior review are included in this updated evidence synthesis. Harms associated with CTC were not evaluated in the prior review.

CT Colonography (CTC). While there were sufficient studies to conduct a recent comprehensive meta-analysis examining the sensitivity and specificity of CTC, ^116^ very few of these studies (four of 33) were conducted in average-risk screening patients. This review, however, provided important indications for which CTC technical approaches affect CTC sensitivity, and the overall consistency of their results. Sensitivity was reduced 4.9 percent for every 1-mm increase in CTC slice thickness, and was higher and more consistent across studies using multidetector CT scanners (MDCT), those using concomitant 2D and 3D imaging, and those using 3D fly-through endoluminal imaging. ^116^

We examined all four studies conducted in average-risk patients from the Mulhall review, but did not further consider three of them based on very small sample sizes (representing only 11 percent of all patients involved in the four studies) and use of older, less accurate scanning technologies. ^148^ – ^150^ We reviewed the remaining study identified for the Mulhall review, ^136^ along with related publications from that study, ^151,^ ^152^ and two newer studies ^137,^ ^138^ conducted in a total of 1781 average-risk patients. Due to differences in methodologies, these data cannot be combined. Two studies provide a range of sensitivities and specificities, with imprecise estimates due to a small number of lesions and study designs primarily aimed at comparing types of technology and/or inter-reader reliability. ^137,^ ^138^ The other study represents the single best published estimate of the accuracy of CTC screening. In this study of 1233 average-risk patients, primary 3D endoluminal CTC had good per-patient sensitivity (93.8 percent) for large (over 10 mm) adenomas, and good sensitivity (88.7 percent) for adenomas 6 mm or larger. CTC sensitivity did not differ from sensitivity of colonoscopy for any size lesion. ^136^ CTC specificity for adenomas 6 mm or greater was considerably lower (79.6 percent) than CTC specificity for adenomas 10 mm or greater (96.0 percent). Based on this study alone, a referral threshold of lesions 10 mm or greater on CTC means that one of every 13 patients screened with CTC would require colonoscopy. A lower threshold for referral (lesions 6 mm or greater) would result in a much higher rate of colonoscopy referral (one out of every three screened with CTC).

Pickhardt, Kim, and colleagues have recently reported a colonoscopy referral rate of 7.9 percent of 3120 patients undergoing primary CTC screening. This rate is based on a protocol of offering referral to colonoscopy for all CTC-detected polyps 6 mm or larger in linear size, with CTC surveillance an option for those with one or two small (6 to 9 mm) polyps. ^182^ Out of a total of 13 percent of patients that were candidates for colonoscopy referral, based on CTC-detected 6 mm or larger polyps, 5.1 percent of patients chose CTC surveillance. Based on this study, between one in eight (if all patients offered immediate colonoscopy accepted it) and one in thirteen patients (if the same proportion elected CTC surveillance) would be referred for colonoscopy after CTC screening.

In this same study, authors also compared yields from CRC screening in average-risk adults undergoing either primary CTC screening (using contrast and primary 3D endoluminal imaging) after physician referral (n=3120), or primary colonoscopy screening after self or physician referral (n=3163) at a single institution. ^182^ While primary CTC and colonoscopy found a similar rate of advanced neoplasia detection (3.2 percent in CTC vs. 3.4 percent in colonoscopy), a higher rate of invasive carcinoma was detected in CTC (0.4 percent, 14 carcinomas in 12 patients), compared with colonoscopy (0.1 percent, 4 carcinomas in 4 patients). Those undergoing CTC screening had a total of 3120 CTC exams and 246 colonoscopy exams, resulting in 561 polypectomies (with no reported complications). Those undergoing colonoscopy screening had a total of 3163 colonoscopies, with 2434 polypectomies and seven (0.2 percent) colonic perforations. The primary limitation of this study is its nonrandomized design, with potential differences between those choosing the different approaches to CRC screening. Further, this study does not establish the impact on health outcomes associated with these two approaches, including the impact of allowing short-term surveillance for those with a few small polyps.

At the time of this report, results from the ACRIN National CT Colonography Trial in average-risk adults have been presented at meetings but not published in complete form. ^222,^ ^223^ This multisite study in 15 private practice and academic centers in the United States has complete evaluations of 2531 asymptomatic, primarily average-risk patients undergoing CRC screening with CTC, followed by blinded colonoscopy done the same day by an undisclosed number of experienced gastroenterology staff. Fecal and fluid tagging were done on all patients. As reported by the study investigators CTC scanners across sites had a minimum of 16 detector rows, and used thin-section images with 0.6 to 1.25 mm collimation, 0.8 to 1 mm reconstruction, and low-dose protocol of 50 mAs; total dose exposure was estimated at 5 mSV per exam. ^220^ Fifteen study-certified readers used both primary 2D and 3D screening approaches. Certification required having read at least 500 CTC cases or attending a 1.5 day training course and passing an examination. Fecal tagging was done on all patients. Based on unpublished results from the press reports of meeting materials, the study found a total of 392 6 to 9 mm polyps in 258 patients and 155 lesions 1 cm or larger in 132 patients. Reported point estimates of the per-person sensitivity of CTC for ≥ 10 mm adenoma was 90 percent and for ≥ 6 mm adenomas was 78 percent, with a specificity of 86–88 percent. These are shown along with findings from Pickhardt et al for CTC and colonoscopy in Table 10 although available data do not allow statistical comparison. Study investigators reported that 8.3 percent (1 in 12 patients) of those undergoing CTC had polyps 6 mm or larger detected, and thus would be referred to colonoscopy; however, study authors also reported a total of 390 patients with lesions 6 mm or larger, suggesting a higher (15.4 percent, 390/2531) referral rate (1 in 6.5 patients). Results have been presented at the September 2007 ACRIN meeting and are expected to be published in the near future. These results must for now be considered preliminary, due to inconsistencies in presented results and lack of detail on study design and execution that would allow critical appraisal and interpretation. Similarly, results from the Munich Colorectal Cancer Prevention Trial of 300 average-risk patients have been presented, but have not been published. Preliminary results suggest similar or better per-patient CTC sensitivity across adenoma sizes (100 percent for 10 mm or greater, 98 percent for 6–9 mm or greater, 80 percent for adenomas 5 mm or smaller) as studies reported here, with the same per-polyp sensitivity as colonoscopy for large adenomas (96.0 percent). This study, however, found lower per-polyp sensitivity of CTC for lesions 6–9 mm (92.1 percent vs. 95.0 percent), and those 5 mm and smaller (78.9 percent vs. 89.5 percent). These results are also preliminary, due to lack of detail on study design and execution that would allow critical appraisal and interpretation.

Table 10 Reported accuracy of CT Colonography

| Colonoscopy | CT Colonography
| Pickhardt 2003 | Pickhardt 2003 | Kim 2007 | ACRIN 2007 (unpublished)
Patients (n) | 1233 | 1233 | 3120 | 2531
Sensitivity (per patient), [95% CI]
Adenoma ≥ 10 mm | 87.5, [74.8, 95.3] | 93.8, [82.8, 98.7] | n/a | 90, [nr]
Adenoma ≥ 6 mm | 92.3, [87.1, 95.8] | 88.7, [82.9, 93.1] | n/a | 78, [nr]
Specificity (per patient), [95% CI]
Lesions ≥ 10 mm | n/a | 96.0, [94.8, 97.1] | n/a | 86, [nr]
Lesions ≥ 6 mm | n/a | 79.6, [77.0, 82.0] | n/a | 88, [nr]
Referral to OC
Lesions ≥ 10 mm | n/a | 1 in 13 | nr | nr
Lesions ≥ 6 mm | n/a | 1 in 3 | 1 in 8–13* | 1 in 6–12**

n/a- not applicable, nr- not reported

* higher estimate because only a few of those persons with lesions ≥ 6mm choose CTC surveillance over immediate colonoscopy followup

** variable estimates based on discrepancies in presented data on proportion with lesions ≥ 6mm

The accuracy of CTC depends on adequate colon cleansing (and perhaps use of contrast materials for addressing residual feces and fluid), adequate distention of the colon, CT techniques and technologies, interpretation by a trained reader, and an appropriate protocol for referral for colonoscopy. ^151,^ ^224,^ ^225^ These are all issues that must be addressed if CTC becomes a recommended test for CRC screening in the community. Expert consensus on best practices for bowel preparation, colonic distention, patient position, use of contrast, and scan parameters for CTC have been published by the American Gastroenterological Society, ^226^ The European Society of Gastrointestinal and Abdominal Radiology (ESGAR), ^227^ and The American College of Radiology. (ACR Practice Guideline. www.acr.org). Accurate CTC interpretation was recognized to require thorough training (review of 50–75 endoscopically confirmed cases, plus additional mentored training), and experts recommend required testing to prove competence. These recommendations are reinforced by the presented (but not published) ACRIN findings, suggesting that half of the 15 radiologists failed the initial certifiying exam (after 1.5 days of training or previous experience in over 500 cases) and required additional training before all eventually passed. ^222^ Experts also agree that interpretation should involve both 2D and 3D images, although primary 3D analysis is increasingly used, based on software advances allowing more time efficiency with 3D analysis. These experts believe that both primary 2D and 3D are acceptable. Comparing primary 2D and primary 3D is largely beyond the scope of this review, but includes differences in examination time, reader time, reader training and preference, and software availability. This debate is further complicated by the rapid evolution of CTC technology and techniques, with at least 9 vendors of CTC software currently in the United States. ^153^ The relative accuracy and availability of researched CTC technologies, compared with community CTC technologies, affects the likelihood that research findings will be translated into community practice.

Harms with CT colonography (CTC). The best estimates of adverse events from CTC screening come from three prospective cohort studies (n=4707) and the asymptomatic subgroup of a large retrospective study (n= 11,707), which did not find any evidence for clinically significant adverse events, including perforation. ^136,^ ^189,^ ^190,^ ^228^ These studies do not, however, address the potential risk for malignancy due to low-dose ionizing radiation.

We identified no studies directly measuring the risk for stochastic effects (i.e., cancer) caused by radiation exposure from CTC. We can indirectly estimate these adverse effects, however, based on the range of effective radiation dose for CTC reported in the literature and estimate for lifetime attributable risk of malignancy (i.e., all solid cancers and leukemia) based on the National Research Council's BEIR VII- Phase 2 report findings. ^229^ Data are inadequate to quantify whether risk for noncancer diseases exist for low-dose radiation exposure. Based on the current evidence, the median effective radiation dose for CTC is approximately 10mSv for dual positioning, both supine and prone. However, newer, low-dose multi-detector CT protocols, with about half the current radiation exposure, may yield similar diagnostic accuracy (or test characteristics). ^230^ For radiation produced in CT scanners, the effective dose equivalent (Sv) is the same as absorbed dose (Gy) (i.e., 1 mSv = 1mGy). ^158^ Given that the average amount of radiation that one is exposed to from background sources in the US is about 3.0 mSv per year, ^229^ ionizing radiation from a single CTC exam is low. However, even low doses of ionizing radiation may convey a small excess risk of cancer. ^231,^ ^232^

Most experts in radiation exposure consider the current report from the National Academy of Sciences' National Research Council's (NRC) on the impact of low-emission radiation on human health the definitive resource of radiation risk. ^229^ Based on this report, the committee predicts that approximately one additional individual per thousand would develop cancer (solid cancer or leukemia) from an exposure to 10mSv above background using the linear no-threshold model (LNT); in comparison, 420 individuals per thousand would be expected to develop cancer from other causes over their lifetimes. Because of limitations in the data used to develop risk models, the risk estimates are uncertain and variation by a factor of two or three cannot be excluded. ^229^ Multiple organizations support the LNT model to estimate potential harms for radiation exposures less than 100mSv, including the NRC, the International Commission on Radiological Protection (ICRP), the US National Council on Radiation Protection and Measurements, the United Nations (UN) Scientific Committee on the Effects of Atomic Radiation, and the UK National Radiological Protection Board. Other organizations, however, believe that the LNT model is an oversimplification and likely overestimates potential harms for low-dose radiation exposures, including the Health Physics Society (HPS), the France Academy of Sciences/National Academy of Medicine, and the American Nuclear Society. ^233^ The effective radiation dose in CTC targets the abdomen and would not likely increase the risk of certain prevalent cancers (e.g., cancers of the breast, thyroid, or lung). Leukemia or abdominal organ cancer risk may remain. This risk estimate is consistent with other published literature on radiation exposure risk from computed tomography. ^195,^ ^232^ Given the uncertainty surrounding the risk of low-dose ionizing radiation from CT exams versus benefit, this is an area of research that needs serious consideration if CT exams are to be used routinely in population-based screening programs requiring serial exams.

Extra-colonic findings on CT colonography (CTC). It is not yet clear if extra-colonic findings detected on CTC constitute a net health benefit or harm. In a recent review of studies reporting extracolonic and incidental findings on CTC, about 40 percent of patients (n=3488) were reported to have abnormalities, and many had more than one abnormality. ^234^ In the current literature, classification of extra-colonic findings into “high,” “moderate,” and “low” clinical significance is variable. “High,” however, generally includes findings that require surgical treatment, medical intervention, or further investigation (e.g., indeterminate solid organ masses or chest nodules, abdominal aortic aneurysms 3 cm or larger, aneurysms of the splenic or renal arteries, adenopathy greater than 1 cm). Findings of “moderate” clinical significance do not require immediate medical attention, but would likely require recognition, investigation, or future treatment (e.g., calculi, small adrenal masses). Findings of “low” clinical significance do not require further investigation or treatment.

Extra-colonic findings of “high” clinical significance are common, ranging from approximately 4.5 to 10 percent in asymptomatic populations, ^136,^ ^228,^ ^235^ – ^237^ up to 23 percent in symptomatic populations undergoing CTC. ^228,^ ^237,^ ^238^ Extra-colonic findings of “moderate” clinical significance are equally as common, ranging from 5 to 27 percent. ^136,^ ^228,^ ^236^ – ^240^ Because extra-colonic findings of both “high” and “moderate” clinical significance generally require medical followup, ^235,^ ^236,^ ^240^ the potential for significant additional morbidity and cost remains. Only a minority of these findings, representing approximately zero to 13 percent of those undergoing CTC, ultimately warrant definitive treatment (e.g., abdominal aortic aneurysm repair, resection of malignancy, chemotherapy for metastases). ^228,^ ^235^ – ^238^ The studies used to generate these estimates, however, vary greatly in study quality (i.e., ability to accurately assess followup) and the duration of followup, the longest of which was 2 years. Thus, none of these studies are able to articulate the true net health benefit or harm for individuals undergoing CTC due to extra-colonic findings.

### Colonoscopy

Three CTC screening studies in 1781 average-risk patients reported the sensitivity of colonoscopy based on comparing initial colonoscopy findings with CTC results, after second-look colonoscopic re-examination to clarify false-negative colonoscopic findings from false-positive CTC findings. ^136^ – ^138^ The proportion of missed adenomas or adenocarcinomas varied considerably, complicated by small numbers of study participants and lesions detected, and differences in the number and experience of the endoscopists in the study. Due to differences in study quality and design, data from these studies cannot be combined; the largest, good-quality study (n=1233) represents the single best estimate currently available for the sensitivity of colonoscopy when compared to a reference standard other than repeat colonoscopy. ^136^ In this study, in which colonoscopy was conducted by 17 experienced gastroenterologists, per-person sensitivity for adenomas 6 mm or larger was 92 percent, for adenomas 8 mm or larger was 92 percent, and for adenomas 10 mm or larger was 88 percent. One of two CRC lesions was detected by colonoscopy, while CTC detected both. The sensitivities of colonoscopy and CTC were not statistically different in this study, and also appeared comparable in the smaller studies. In the other two studies, limits in the size, design, and primary purposes limit their ability to provide informative estimates of sensitivity and specificity for polyps or for CRC. However, colonoscopy missed adenocarcinomas in two of these studies, which emphasizes that colonoscopy is clearly not 100 percent sensitive and may miss important lesions. Findings from tandem colonoscopy studies—most conducted in relatively high-risk patient samples—provide another perspective. Van Rijn et al. ^241^ conducted a meta-analysis of colonoscopy miss rates in 2006 using six studies of 465 patients. ^241^ Endoscopists missed very few large (≥ 10 mm) adenomas (2.1 percent, CI 0.3, 7.3 percent), but more smaller adenomas 5 to 10 mm size (13 percent, CI 8.0, 18 percent) and under 5 mm (26 percent, CI 27, 35 percent). These studies used experienced endoscopists and reported per-polyp (rather than per-patient) miss rates. Missed or interval CRCs have also been estimated using colonoscopies performed one to five years apart, but none of these studies met our criteria. None conducted repeat colonoscopy within 3 years of an initial screening colonoscopy conducted in average-risk asymptomatic persons. One study estimated missed colorectal tumors occurred in 3.4% of a population-based cohort (n = 12 487) who had previously undergone colonoscopy for any reason up to 3 years before a new diagnosis of colorectal cancer. ^242^ However, since these studies are commonly referred to as representing community performance for colonoscopy, they are summarized in Appendix C Table 5. Recognizing there may be suboptimal endoscopic examinations and variation in practice, experts recommend standard approaches to improve quality of colonoscopies, including specifying adequate bowel preparation and adequate time devoted to the examination, particularly during withdrawal of the colonoscope. ^241,^ ^243^

Harms from Colonoscopy. From a total of 11 studies (n=55,211), we found that serious complications from colonoscopy are not uncommon—3.1 per 1000 procedures, 95 percent CI (1.7 to 5.8 per 1000 procedures). These complications include perforation, hemorrhage, diverticulitis, cardiovascular events, severe abdominal pain, and death. Few studies (three of 11) reported whether colonoscopies included polypectomies or not, which is a major flaw in the available research. In the three studies with polypectomy rates, 41 percent to 68 percent of colonscopies involved polypectomies and more than 85 percent of serious complications, perforations, or major bleeding were in colonoscopies with polypectomy. In a meta-regression, we found that study setting by country (US compared with non-US) had a statistically significant effect on rates of perforation. Therefore, we also reported stratified analyses in an attempt to derive estimates that are more relevant for US policy-making. Total serious complications from colonoscopy in the six studies conducted in the US were slightly lower, 2.9 per 1000 procedures, 95 percent CI (1.2 to 7.6 per 1000 procedures), but not clinically different. Because of the limited number of studies, as well as the limited reporting and homogeneity of many individual study-level characteristics, our meta-regression had limited ability to detect the effect other potentially important factors—such as the rate of polypectomies, operator characteristics, or patient age and sex—have on the estimates of harms for colonoscopy.

Case reports of fatal or near-fatal outcomes in average-risk persons undergoing routine colonoscopy include splenic rupture, ^244^ – ^246^ retroperitoneal gas gangrene, ^247,^ ^248^ small bowel perforation, ^249^ colonic gas explosion with electrocautery, ^250^ and appendiceal abscess resulting in death. ^251^ In addition, there have been case reports of transmission of communicable diseases using unsanitized colonoscopes ^252^ and chemical colitis from glutaraldehyde, which is used to disinfect endoscopes. ^253^

### Flexible Sigmoidoscopy (FS)

Large-scale screening colonoscopy and FS cohort studies or trials report the probability of proximal colonic lesions associated with distal findings. Findings from these studies were used to calculate the sensitivity of two FS screening protocols: 1) colonoscopic referral for any distal lesion located on FS examination (e.g., FS without biopsy) and; 2) colonoscopic referral for biopsy-proven adenomas on FS examination (FS with biopsy).

Estimates of sensitivities for these two FS protocols do not appear to substantially differ, although they are not based on large numbers. The estimated sensitivity of FS without biopsy, for CRC in the entire colon, is 75 percent (based on a single study of 1994 adults, with 12 total CRCs detected), ^59^ while the sensitivity for advanced neoplasia in the entire colon ranged from 76.8 to 85.6 percent (from two studies in 6146 adults with 514 advanced neoplastic lesions detected). ^60,^ ^146^ The estimated sensitivity of FS with biopsy (assuming colonoscopy referral for advanced neoplasia, or three or more adenomas) for CRC throughout the colon ranged from 58.3 to 62.5 percent (based on two studies in 3982 adults with 20 total CRCs detected). ^58,^ ^59^ The sensitivity of FS with biopsy for advanced neoplasia in the entire colon ranged from 71.8 percent to 85.3 percent, based on reports of 1028 advanced neoplasias detected during 14, 938 colonoscopies in average-risk screening populations. ^58^ – ^61,^ ^144^ – ^146^ A single study estimated a much lower (50 percent, 36/72 lesions) sensitivity of FS with biopsy for detecting advanced neoplasia in a sample of 1463 women examined at military medical centers. ^61^ This study has been cited as indicating a much higher FS miss rate for proximal neoplasia in women, particularly when compared to findings in men using the same protocol. ^254^ Another study comparing women and men in a workplace screening program, however, suggested that FS with biopsy was equally or more sensitive in women (78 percent, 32/41 lesions), compared with men (70 percent, 98/140 lesions), for advanced neoplasia throughout the colon. ^146^ The limitations of sensitivity estimates based on colonoscopy findings must also be considered. These calculations are likely to be an overestimation, as they presume that polyps detected by colonoscopists would be as likely to be identified by those trained to perform FS; these simulations mostly estimate that FS exams successfully extend to the splenic flexure. Where this has not been assumed, FS sensitivity estimates are lower. ^60,^ ^61^ Whether an individual FS examination reaches even the descending colon depends on the patient's size and anatomy, the quality of the bowel preparation, the patient's tolerance of discomfort, and examiner skill. ^255,^ ^256^

In these screening colonoscopy cohorts, the prevalence of an isolated advanced proximal neoplasia ranged from 0.8–3.2 percent, indicating that while the distal portion of the colonoscopic exam showed no lesions, the proximal portion did. These lesions would not be detected (i.e., would result in false negative examinations) using any FS protocol. Since most studies used the splenic flexure to determine which lesions would be distal enough to be located by FS, prevalence of isolated proximal neoplasia is also likely underestimated. A single study compared using the splenic flexure to define the distal colon to using a more limited, and perhaps pragmatic, definition (i.e., the junction of the sigmoid and descending colons). This study found the prevalence of isolated proximal neoplasia increased from 2.4 percent to 3.4 percent using the more limited definition. ^61^ While concern has been raised about the high proportion of advanced neoplasias missed by FS (one-third to one-half) due to their proximal location, one must recall that the natural history of advanced neoplasia is unknown. Also, Farraye et al. have pointed out that the proportion of proximal lesions missed with FS could potentially be reduced by targeted screening approaches, such as selection of low-risk patients. ^257^ Targeted screening approaches are discussed briefly below.

Determining whether the sensitivity of FS protocols differs is an important issue, since established standards are currently lacking for which FS findings should prompt colonoscopy referral. ^255^ Biopsies do not appear to be routinely conducted on most polyps found during screening FS in the US. ^146^ Also, completed and ongoing FS trials vary in their protocols for colonoscopy referral. The small RCT of FS included in the last USPSTF review, ^6^ and current PLCO trial, ^142^ both used visual criteria without biopsy for colonoscopic referral, while the UK Flexible Sigmoidoscopy Screening Trial (UKFSST), ^83^ the SCORE trial, ^82^ and the NORCCAPS trial ^81^ are basing colonoscopic referral on biopsy-based criteria. Other between-trial differences, which have been recently summarized, ^147^ will be important to consider as these trial results become available.

While specificity could not be estimated from these simulations using screening colonoscopy trials, the PLCO trial has reported that followup colonoscopies in those with large polyps on FS detected no adenomas in 20 to 23 percent of patients, generating a specificity estimate of 77 to 80 percent. ^54^ This specificity estimate is likely to be an underestimate, particularly for FS with biopsy protocols, as referrals were based on any visual lesion.

Based on a single-tandem FS study, ^141^ and two small short-term followup (3 years) studies of those with negative FS findings, about 20 percent of all adenomas (14 percent of those ≥ 10mm) were missed on first exam. Of those screened, 0.8 percent had advanced neoplasias (none were adenocarcinomas) within reach of the FS that could have been missed on first exam. About 20 percent of all adenomas (14 percent of those larger than 10 mm) were missed on first exam. ^54,^ ^143^ Since these estimates are not precise due to their small numbers, their significance lies in reinforcing the importance of endoscopist skill and patient preparation for FS and colonoscopy. Even among trained and experienced FS examiners (gastroenterologists or surgeons) in the UKFSST, adenoma detection rates varied significantly between the examiners in the proportion of patients with at least one detected adenoma. ^258^ Differences between thirteen examiners ranged from 8.6 to 15.9 percent, and could not be accounted for by patient sex, age, family history of CRC, or cigarette smoking. This variation has been taken to represent the range of skills among endoscopists. Thus, quality standards for those conducting FS and colonoscopy are important.

Harms of flexible sigmoidoscopy. Serious complications from FS in average-risk populations (n=126,985) are much less common than colonoscopy, 3.4 per 10,000 procedures, but estimates for FS harms encompass a much wider range, 95 percent CI (0.61 to 19 per 10,000 procedures). Serious complications include perforation, hemorrhage, diverticulitis, cardiovascular events, severe abdominal pain, and death. For the same reasons discussed in “Harms of colonoscopy” section, we reported stratified analyses by country of study setting in an attempt to derive estimates that would perhaps be most relevant. Because of the limited number of studies in the US (n=2) that reported total serious complications from FS, however, these estimates, 0.9 per 10,000 procedures, 95% CI (2.0 per million to 49.5 per 10,000 procedures), are not clinically different or more helpful than the estimates derived from all the studies.

### Small polyps and implications for CRC screening

Unanswered questions remain about the natural history of adenomas under 10 mm and, therefore, about their clinical significance. Clarifying the risk associated with smaller polyps will be critical for estimating the true sensitivity and specificity of current and future CRC screening methods that directly visualize lesions for referral to colonoscopy (e.g., CTC, FS). Without the benefit of biopsy results, referral is based on polyp size. Risk from a small polyp visualized by CTC is related to whether the visualized polyp has a reasonable probability of containing advanced adenoma or carcinoma that will progress to invasive cancer before a next examination. On a FS in which no biopsy is taken, a small polyp can imply risk in two ways—it may contain advanced adenoma or in situ carcinoma, or may be a “sentinel” lesion signaling the probable presence of a high-risk adenoma or cancer elsewhere in the unexamined proximal colon. Ultimately, test performance for both CTC and FS (without biopsy) will depend on what lesion size (and type) is considered to indicate a positive test. As such, the effectiveness (and cost-effectiveness) of these screening techniques will vary accordingly.

### Harms of bowel preparation for CT colonography (CTC), colonoscopy, and flexible sigmoidoscopy (FS)

Common bowel preparation agents for FS include enemas and occasionally oral laxatives. Common bowel preparation agents for colonoscopy or CTC include polyethylene glycol (PEG) solution, oral sodium phosphate (NaP) solution, sodium picosulphate (SPS), with or without additional oral laxatives. Common minor adverse events include nausea, vomiting, abdominal pain, abdominal distension/bloating, anal irritation, headache, dizziness, electrolyte abnormalities (e.g., hyponatremia, hypokalemia, hypocalcemia, hyper- or hypophosphatemia), and poor sleep. Clinical trials comparing bowel preparations revealed variations in the prevalence of these side effects, ranging from 15 to 95 percent. ^259^ – ^266^ Serious adverse events (e.g., severe dehydration, symptomatic electrolyte abnormalities) in these trials were limited to persons with major predisposing illnesses, incorrect dosing of NaP, or use of NaP in persons with pre-existing renal impairment. ^264,^ ^267^

In one fair-quality systematic review, NaP appeared more easily completed than PEG, but NaP and PEG were comparable in terms of total number of minor adverse events, such that persons receiving PEG had slightly higher rates of abdominal pain, but persons with NaP had slightly higher rates of dizziness and asymptomatic electrolyte abnormalities. ^260^ Another recent fair-quality systematic review also found that NaP and PEG had similar tolerability and no difference in efficacy of bowel preparation. This review also found no clinically significant adverse events from these bowel preparations in the trials included in the review. ^268^ NaP is generally avoided, however, in persons with renal impairment (includes older patients with reduced glomerular filtration rates (GFR)), cardiovascular impairment (e.g. CHF, recent myocardial infarction), major upper or lower GI motility disturbances, GI malabsorption, pre-existing electrolyte abnormalities, restricted oral intake (inability to rehydrate), and ascites. ^264^

We found no evidence of clinically significant adverse effects due to bowel preparation requiring hospitalization in average-risk screening populations preparing for FS, colonoscopy, or CT colonography, except for one person with “water intoxication” due to “over anxious bowel cleansing” in preparation for FS, ^6^ and one person with severe diarrhea. ^173^ Case reports of serious adverse events from bowel preparation in average-risk persons undergoing colonoscopy include acute renal failure and acute phosphate nephropathy in persons who received bowel preparations with sodium phosphate, ^264,^ ^269,^ ^270^ one person with ischemic colitis who received bowel preparation with NaP, ^264^ one person with symptomatic hypokalemia with NaP, ^264^ and one person with a seizure secondary to hyponatremia with PEG. ^271^

## Emerging Issues

### Special Population Issues in CRC

Race. Compared with same-sex persons in other racial/ethnic subgroups, Black men and Black women have the highest age-adjusted incidence of CRC and the highest proportion of CRC occurring in proximal locations in the colon (Table 2). When examined by subsite, Black men have the highest age-adjusted incidence rates for all subsites except the rectum and Black women have the highest age-adjusted incidence rates among women at every subsite. ^272^ These differences have recently been found to apply to colorectal polyps and cancers. Using data from the Clinical Outcomes Research Initiative (CORI), researchers examined screening colonoscopy results in 3195 average-risk Blacks and 43,431 average-risk Whites. ^273^ Blacks had fewer total polyps (35 percent vs. 38 percent with polyps), but more of these polyps were proximal to the splenic flexure (57 percent vs. 51 percent). A much higher proportion of Blacks with polyps had proximal polyps only (42 percent of Blacks compared with 30 percent of whites). In multivariate analyses controlling for age and sex, Blacks had higher odds of proximal polyps (adjusted OR 1.30, CI: 1.11, 1.52), higher odds of colonic tumors (adjusted OR 1.78, CI: 1.14, 2.77), and higher odds of proximal tumors (adjusted OR 4.37, CI: 1.16, 16.42).

Blacks have a worse CRC prognosis than Whites. In lesions across anatomic subsites, Blacks are more likely than Whites to present with advanced late-stage, rather than localized, disease. ^272,^ ^274^ Even after adjusting for stage at CRC diagnosis, Blacks have higher CRC mortality rates than whites. ^272,^ ^275^ Blacks are also more likely to be diagnosed with cancer before age 50 (10.6 percent of cancers) than Whites (5.5 percent). ^276^

These data (and others) have led to calls to consider screening Blacks beginning at age 45. ^277^ Recent publications also suggest that colonoscopy may be the preferred screening approach for Blacks due to differences in polyp and cancer location in Blacks. ^278^ Blacks tend to be less likely to be current on CRC screening than Whites and are less likely to have had screening colonoscopy, although differences are statistically significant only in women. ^103^ Although current CRC screening uptake is also inferior in Latinos and other Nonwhites, the higher burden of disease in Blacks makes their screening issues a particular concern.

Sex. Findings from this review challenge several often-cited studies that have been interpreted to indicate that colonoscopy may be the preferred CRC screening method for all women, due to the higher proportion of advanced proximal neoplasias potentially missed by FS examination in women compared with men (64 percent vs. 34 percent). ^60,^ ^61^ These studies compared similar protocols using screening colonoscopy to simulate FS and its ability to detect advanced proximal neoplasia. Lieberman and colleagues screened 3121 predominantly male veterans aged 50–75 years (mean 63 years) and found a sensitivity of FS with biopsy of 81.7 percent. In contrast, the sensitivity from the main analysis reported by Schoenfeld and colleagues for FS with biopsy in 1463 women from military medical centers aged 40–70 years (mean 59 years) was 34.7 percent. When the same definition for “distal lesion” is used in both studies, the re-calculated sensitivity of flexible sigmoidoscopy for advanced proximal neoplasia is 50.0 percent in women. ^61^ Although the prevalence of proximal neoplasia is lower in women (4.9 percent) than men (10.5 percent), close to the same percentage of women (2.4 percent) and men (1.9 percent) would have had advanced proximal neoplasms that would be missed if screened using flexible sigmoidoscopy. The only other study in our review, by Imperiale and colleagues, reporting colonoscopy results by sex found a lower prevalence of proximal advanced neoplasia in women (1.2 percent), compared with men (3.9 percent). This study from a worksite setting also found a lower risk for isolated proximal advanced neoplasia in women (0.84 percent) than men (2.5 percent). Calculated sensitivity for flexible sigmoidoscopy (with biopsy) was similar or slightly lower in men (70 percent) compared with women (78 percent). This study's data suggest that men, rather than women, would have a greater proportion of proximal lesions missed by flexible sigmoidoscopy. When multivariate analyses of risk for advanced proximal neoplasia have been performed, older age, male sex, and distal adenomas are consistently identified as risk factors. ^58,^ ^59,^ ^144^ Similarly, isolated proximal neoplasia is more common in those over 60 years old, those with a family history of CRC, and smokers. ^58^ Differences in the prevalence of these risk factors for isolated proximal neoplasia among the study populations may explain some of the differences noted above in studies estimating the performance of FS in women.

Other issues, however, have been raised in terms of appropriate CRC screening approaches for women, including a higher risk for inadequate or limited endoscopies. ^279,^ ^280^ Women have a longer colonic length (median of 155 cm compared with a median of 145 cm in men), which may contribute to greater technical difficulty and discomfort during both flexible sigmoidoscopy and colonoscopy in women. ^280,^ ^281^ Prior hysterectomy may be a risk factor for incomplete examination. ^281,^ ^282^ Women may better tolerate the use of pediatric colonoscopes for colonoscopy or upper endoscopes for flexible sigmoidoscopy. ^283^

Older adults. While consideration of starting and stopping ages was beyond the formal scope of this systematic review, recent analyses have looked at factors beyond age to determine the probable benefit from CRC screening in older adults (i.e., age 75 years and older). Lin and colleagues used SEER data to model the expected life years gained among 1244 patients undergoing screening colonoscopy by comparing older adults (age 75 years and older) with younger adults (age 50–54 years). ^284^ While the prevalence of neoplasia increased with age, modeled mean increases in life expectancy were considerably lower in those aged 75 years and older, suggesting a reduced benefit of CRC screening in older adults. In a separate analysis of 35,755 Medicare patients, however, co-morbidities that were predictive of decreased 5-year life expectancy appear to provide more effective means of determining who could benefit from screening among adults 67 years and older than age alone. ^285^ Life expectancy in men and women after CRC diagnosis is significantly lower in those with three or more chronic conditions, compared with those with no chronic conditions, regardless of stage of disease or age at diagnosis. Thus, a female patient aged 81 years with no chronic conditions has a 13.8 year life expectancy and could potentially benefit from CRC screening more than a younger woman or man with three or more chronic conditions. Others who have considered in detail the complexities of inferring the evidence about CRC screening from younger to older adults also conclude that life expectancy, health status, benefits and harms of different tests, and patient preferences should all be factors when considering CRC screening in those over age 75–80 years. ^286^ Unfortunately, we found very little evidence to support or refute increased harms of CRC screening in older adults. Two studies ^170,^ ^171^ showed that persons aged 60 years and older have increased rates of major complications from colonoscopy (e.g., perforation, major bleeding, and hospitalization for diverticulitis). Many studies that reported potential harms from colonoscopy included older adults, ^170^ – ^172,^ ^174,^ ^176^ – ^178,^ ^180,^ ^183^ but do not provide enough information to interpret harms by age subgroups. Overall, these studies do not appear to have different proportions of harms than studies that exclude older adults. ^136,^ ^181^ As with expected benefits from screening, risk of harms may be more related to overall health status than to age in older adults.

### Targeted (Customized) Screening Recommendations

Current CRC screening recommendations are made for all adults alike, except for differentiation based on family history and age. Those without a family history are recommended to begin CRC screening at 50 years of age, the age at which CRC incidence begins to substantially increase. The concept of further customizing CRC screening recommendations has become more compelling as we have learned more about differences in the epidemiology of adenomatous polyp and CRC development based on age, sex, and race/ethnicity. ^287^ – ^289^ Targeted screening recommendations could potentially address the timing of screening initiation, preferred screening method(s), or both. In theory, targeted screening has the potential to improve CRC screening program performance and efficiency. Data evaluating the health or economic impact of targeted screening approaches, however, are quite limited.

In an effort to identify candidates at low risk for advanced proximal neoplasia who could be offered flexible sigmoidoscopy screening instead of colonoscopy, Imperiale and colleagues created and validated a novel index based on age, sex, and sigmoidoscopy findings within a split sample from a dataset of 3025 screening colonoscopy results. ^146^ The index resulted in scores from 0–7 points. A low score was 0 or 1 point. In the validation sample (n=1031), about half of patients had a low score. Advanced proximal neoplasia was rare (0.4 percent) in those with a low score. For women (score 0 for sex) under aged 60 (score 1 for age), only those with advanced lesions in the distal colon had a higher risk of advanced proximal lesions. The authors point out that if this index were validated in other populations, women under 60 without significant distal lesions, and others at lower risk based on age, sex, and distal findings, could be those for whom sigmoidoscopy alone is an entirely sufficient screening test.

Betes et.al. have sought to use characteristics other than family history of CRC to identify candidates at increased risk for advanced adenomas and who could potentially benefit from preferentially selecting screening colonoscopy for primary CRC screening. ^144^ Using a dataset of 2260 primary screening colonoscopies in average-risk patients aged 40 and older, these researchers created a scoring system based on sex, BMI, and age. Scores ranged from 0–8. The validity of the scoring system was assessed by ROC analysis, with an area under the curve of 67 percent, which indicates a somewhat useful score. Two percent or fewer patients with a lower score (0–2) had advanced adenoma anywhere in the colon. Women (score 0) under aged 60 (score 0) were considered low risk, even if they were markedly obese (BMI>35, score 2).

### Screening Programs

National screening programs are being implemented in the UK, Australia, Finland, and elsewhere. In the US, many health plans are aggressively targeting colorectal cancer screening (a HEDIS quality of care measure since 2004) and the CDC is funding multiple state and community initiatives to increase CRC screening, including CRC-screening demonstration programs for low-income under- or uninsured men and women. ^105^ As these programs are evaluated, they could provide additional information about whether the natural variation inherent in these screening programs affects the resulting participation and, ultimately, health benefits or harms. Additionally, CDC's Community Task Force should soon publish a series of systematic reviews related to increasing screening rates for colorectal (along with breast and cervical) cancer. ^290^ These reports address strategies to increase community demand for preventive services, community access to recommended screening, and the use of provider reminders, incentives, and performance feedback to increase providers' actions to recommend, offer, and deliver CRC screenings.

### Developing Technologies

Technological advances in new or existing CRC screening methods are occurring rapidly. This rapid development requires prudence when considering the evidence supporting specific technologies, and will require care during the implementation process ifthese technologies are recommended for community-based screening programs.

There are ongoing developments in the use of “virtual colonoscopy”, particularly CT colonography (CTC); efforts are underway to develop or validate better imaging techniques, computer-aided detection software, and cathartic-free approaches with fecal tagging. ^291^ – ^294^ Evaluators are considering critical issues in test interpretation that need to be understood, ^295^ and experts are beginning to set quality standards for screening CTCs in the community. MR colonography, which does not use radiation, has also been used for “virtual colonoscopy”. ^296^ However, studies evaluating MR colonography for detection of colonic lesions, including polyps, have been conducted primarily in high-risk populations with a limited number of subjects. ^297^ – ^304^ At the time of this report, the only study in a screening population evaluated the use of dark lumen MR colonography without cathartic bowel preparation in a screening population in Germany. ^221^ While MR colonography was outside the scope of this report, due to the early stage of its development as a potential CRC screening tool, this study signals that MR colonography could be an important test to evaluate in the future.

Fecal testing is a very versatile field, with research ongoing in fecal markers and DNA and RNA testing. ^126,^ ^157,^ ^305^ For fecal DNA testing, novel approaches include amplifying DNA in stool and focused evaluations of the best individual or combinations of markers for maximizing test performance. ^156^ Some markers are focused on detecting adenomas, ^306^ as these are important for preventing CRC. ^307^ Hypermethylation of some tumor suppressor, or other regulatory, genes may help detect risk for adenoma recurrence, ^308^ suggesting a potential role in post-polypectomy surveillance, or possibly even in primary CRC screening. Development of blood assays for DNA is also underway. A number of developing technologies were not evaluated in our review—due to being early in the development process—but are being reported in the literature and may be important in future reviews of CRC screening. These include advances in colonoscopic techniques with magnification, ^309^ – ^311^ use of stains and dyes (chromoendoscopy), ^312^ – ^315^ and other optical adjuncts. ^316^ Some studies are investigating the use of scattering spectroscopy as an optical “biopsy” technique, ^317^ while others have investigated capsule endoscopy as an alternative to colonoscopy. ^318^ A pneumatic self-propelling, self-navigating colonoscope is still in early stages of testing. ^319^ – ^321^ However, newer CRC techniques may be under development for various purposes; therefore, research for the purposes of screening should be distinguished from others, e.g., CRC diagnostic evaluation, or surveillance.

## Ongoing Studies

There are four ongoing RCTs evaluating the effects of various flexible sigmoidoscopy screening protocols (with and without biopsy) on CRC mortality. These are the only ongoing trials of CRC screening we have located that address health outcomes. While some have advocated strongly for a RCT evaluating screening colonoscopy, ^322^ we are not aware that one is currently planned or funded. A diagnostic accuracy study evaluating a multi-target DNA panel (performed in fecal or plasma samples) has been recently completed, with preliminary results presented in abstract only. The preliminary results of the multisite ACRIN study of CTC screening have also been presented and are discussed above. Full evaluation of these results will be possible after publication.

## Limitations

Our review builds on a prior systematic review and, as such, did not re-examine all of the questions previously addressed by this review. In particular, we did not address issues around test acceptability, feasibility, and compliance. Information on recommended CRC endoscopic screening methods was updated to include community performance and mortality outcomes for all recommended or newer CRC screening approaches; in particular, longer-term results from FOBT screening trials were sought. While information on improved or new CRC screening methods that were not recommended previously was considered in depth, we did not comprehensively report the state of the science for each test. Rather, we focused on determining whether adequate studies of clinical accuracy and screening benefits in average-risk asymptomatic populations exist. We summarized these studies where available. This pragmatic approach was necessary given the breadth of this review, but is also appropriate given its primary purpose of providing evidence upon which the USPSTF could base its updated CRC screening recommendation.

Due to our limited scope and timeline, we only reviewed the evidence for “serious harms” (i.e., those complications requiring unplanned medical attention in the form of hospitalizations, emergency room or physician visit, or death). For example, we did not systematically review the evidence for indirect harms (e.g., sequelae from false negative screening exams), psychological harms (e.g., “health certificate effect” from negative exams), or issues around tolerability and acceptability of each exam.

Screening for CRC is a very important public health issue that has been extensively studied over the past 30 years. Given the extensive and expanding international research literature for CRC screening, there are important issues that were beyond the scope of this review. Methods to increase the utilization of recommended CRC screening in the eligible US population were not part of this systematic review. This topic, however, is being addressed by CDC's Community Task Force and others.

Others, such as the US Multisociety Task Force, have addressed issues surrounding surveillance after positive screening, screening in high-risk groups, and rescreening. Rescreening intervals were not part of this review, but are included in the USPSTF's decision analysis, which is reported separately. ^11^ Given the rapid development of new technologies in CRC screening, ongoing gains in understanding the epidemiology and biology of CRC across patient subgroups, and expected results from trials elucidating various screening approaches, this topic requires continuous monitoring and frequent updating.

## Future Research

Within the context of ongoing screening program implementation, well-designed cohort studies in average-risk men and women should compare the performance of novel fecal screening tests with established fecal screening tests. These studies should report test positivity, screening test accuracy, adherence with recommended colonoscopic referral, and health outcomes. Documenting initial and repeat test adherence, other implementation issues, and costs will help further inform policy makers. Studies evaluating the test performance of multiple tests within the same individual, ^160^ rather than comparing different approaches in different populations, ^323,^ ^324^ will provide the most useful data.

Other valuable studies would include:

1 Prospective evaluations of risks associated with small and medium-sized adenomas over 1, 3, 5, and 10 years. Similarly, natural history studies of advanced neoplasia would be very useful.
2 Studies validating the availability and performance of screening CTC that meet minimal technical and proficiency standards in community settings outside specialized or academic settings. These studies should examine yield, test positivity rate, test performance, health care utilization, and reader variability and accuracy.
3 Independent validation of preliminary risk indices based on age, sex, and distal colonic findings for determining appropriate candidates for flexible sigmoidoscopy instead of colonoscopy screening, and determination of the health impact of their use.
4 Development and validation of novel risk indices that incorporate race/ethnicity as a CRC risk factor along with other strong risk factor candidates (e.g., current and/or lifetime smoking exposure).
5 Well-designed cohort studies in average-risk screening populations to evaluate the test positivity, diagnostic yield, accuracy, and efficiency of validated risk indices for determining endoscopic and other CRC screening procedures in average-risk men and women of different racial/ethnic groups (Black, White, Asian/PI, and AI/AN) at different ages.
6 Cross-sectional research on the yield of adenomas, including flat and depressed adenomas, using chromoendoscopy or other optical colonoscopic adjuncts in average-risk patients undergoing primary or secondary colonoscopic screening.
7 Well-designed observational studies with adequate followup to determine the risks versus benefits of identifying extra-colonic findings.

## Conclusions

Since the previous USPSTF review, evidence has accrued about novel CRC screening methods, including FITs, CTC, and fecal DNA testing. Screening for CRC has a rapidly evolving science base, such that guidance may change as more research becomes available.

Currently, based on test performance characteristics alone, a case could be made for substituting specific FITs (Magstream and perhaps FlexSure OBT) for guaiac FOBT tests to gain sensitivity in FOBT screening programs without losing specificity. Based on these test performance criteria (gain in sensitivity without loss of specificity) alone, Hemoccult Sensa may not be a good substitute for Hemoccult II or comparable guaiac tests. However, for most fecal tests there is not evidence to support a simple substitution. In these cases, clarifying the incremental benefits and harms (and net impact) from substituting newer fecal screening tests for older guaiac tests, in the context of an FOBT screening program for CRC, were beyond the scope of this review, but are addressed in the companion decision analysis.

Clinical accuracy studies of CT colonography (CTC) may justify its consideration for population CRC screening, particularly if one accepts that important lesions for detection and referral are those 10 mm or larger. However, the apparent accuracy of CTC (compared with colonoscopy) must be balanced against what we know about potential short-term and long-term harms, particularly from low-dose ionizing radiation, or the impact of extra-colonic findings. Further, potential variability in CTC test accuracy and safety that could occur with widespread performance in the community needs to be addressed. Fecal DNA screening studies in average-risk populations are too limited to support considering this approach for population CRC screening, particularly given the ongoing and rapid evolution of these technologies.

The estimated sensitivity of flexible sigmoidoscopy, with and without biopsy, for advanced neoplasia throughout the colon ranges from 72 to 86 percent, with possibly lower (but less precise) estimates for CRC throughout the whole colon (59 to 75 percent). Imperfect sensitivity of flexible sigmoidoscopy is not new and may result from many factors, including limited examination of the colon, variable performance by examiners, lack of standardized protocols for colonoscopic referral, and differing risks for advanced proximal neoplasia among patients. More accurate considerations of the benefits of flexible sigmoidoscopy screening programs will be clear only after current RCTs are reported. Colonoscopy misses fewer large lesions than flexible sigmoidoscopy, but recent comparisons with CTC, along with other research, illustrate the importance of high quality examinations. While neither colonoscopy nor flexible sigmoidoscopy is 100 percent sensitive, they remain important means for detecting and treating CRC and its precursor lesions (adenomas). As well, colonoscopy plays an important role as part of the final pathway for other screening tests. As such, quality criteria and standards for community endoscopy for CRC screening are also important. Additionally, potential harms associated with colonoscopy are not negligible, as serious complications from screening colonoscopy in average-risk populations occur in 31 per 10,000 procedures, 95 percent CI (17 to 58 per 10,000 procedures), and are ten-fold more common than serious complications with flexible sigmoidoscopy.

More targeted CRC screening recommendations that maximize population CRC screening benefits, while minimizing associated harms, are worth investigating. Upgrading community performance of screening endoscopies through quality improvement standards and monitoring may also help reduce procedure-related harms. Similar efforts to ensure high-quality community implementation will be necessary as new tests become recognized as valid CRC screening tests.