# Key Questions & Results

We condensed the findings for each key question into a summary table and abbreviated text summarizing these studies, which makes presenting the large number of detailed studies possible. Details for each of the studies included in each key question are addressed in the detailed evidence tables and descriptive text included in the Appendices. Where 95 percent confidence intervals are reported, they are abbreviated as “CI”.

## Key Question 1. What is the effectiveness of the following screening methods (alone or in combination) in reducing mortality from colorectal cancer: flexible sigmoidoscopy (FS), colonoscopy, CT colonography (CTC), fecal screening tests?

We found no new trials or well-designed cohort or case-control studies of FOBT screening programs reporting mortality. Recent publications, however, provide data on longer-term followup after 12–18 years in two of the three RCTs of FOBT screening programs included in the previous USPSTF report. ^131,^ ^132^ Additionally, another FOBT trial ^133^ included in the previous report has made mortality data available to other authors for meta-analysis. ^94^ For other established CRC screening modalities (e.g., colonoscopy or FS), and for newer CRC screening methods (e.g., CTC, new fecal screening tests), we found no new trials or well-designed cohort or case-control studies that reported CRC mortality, and no reports of longer-term followup of previously identified trials.

Mortality data from the longest time point of followup for each of the FOBT screening trials is included in Table 3. While biennial FOBT screening programs generally reduced CRC mortality 13 to 21 percent after 8 to 13 years of screening, ^3,^ ^4,^ ^132,^ ^134^ two trials did not show mortality benefit until after 15–18 years of screening. ^94,^ ^135^ All trials used the Hemoccult II brand of FOBT, but screening programs differed in several important ways: 1) whether they rehydrated the FOBT samples prior to testing; 2) what number of positive FOBT results defined a “test positive”; and 3) the work-up used for positive FOBT results. In one trial that reported a 16 percent CRC mortality reduction after 17 years of biennial screening using nonrehydrated FOBT, ^131^ recalculation of CRC mortality after including CRC treatment-related deaths, however, reduced this benefit to 11 percent (no longer a statistically significant reduction). We were unable to interpret this finding, due to very limited details about how deaths were classified. And, while none of these trials found a reduction in all-cause mortality from screening, two issues in these trials undermine the expectation for an effect on all-cause mortality; first, CRC mortality was a relatively low contributor to overall mortality; and, second, there was limited power. Both issues lead to a loss of precision in estimates of all-cause mortality.

Table 3 Key question 1 summary table

Study | Sample Demographics | CRC incidence (per 1000) | CRC mortality rate (per 1,000 persons) | RR
Annual Screening
Minnesota (USA) Mandel 1993 ^5^ | Sample size: S: 15,570; C: 15,394 Ages: 50–80 % female S: 52; C: 52 | S: 23 persons; C: 26 persons | 13 yrs NR (cumulative mortality) | 0.67 (0.50–0.87)
Minnesota (USA) Mandel 1999 ^135^ Mandel 2000 ^325^ | S: 32 persons; C: 39 persons | 18 yrs (5 yrs; end of screening period) NR (cumulative mortality) | 0.67 (0.51–0.83)
Biennial Screening
Nottingham (UK) Hardcastle 1996 ^3^ | S: 76,224; C: 76,079 Ages: 50–74 % female: NR | S: 1.49 person yrs; C: 1.44 person yrs % of Dukes A: S: 20%; C: 11% P<0.001 | 7.8 yrs median S: 0.60; C: 0.70 | 0.85 (0.74–0.98)
Nottingham (UK) Scholefield 2002 ^132^ | S: 1.51 person yrs; C: 1.53 person yrs % of Dukes A: NR | 11.7 yrs (median) (5 yrs after end of screening period) S: 0.70; C: 0.81 | 0.87 (0.78–0.97)
Funen (Denmark) Kronborg 1996 ^4^ | S: 30,762; C: 30,966 Ages:45–75 % female: S: 51.7; C: 53 | S: 1.71 person yrs; C: 1.72 person yrs % of Dukes A: S: 22%; C: 11% P<0.01 | 10 yrs (5 screening rounds) S: 0.65; C: 0.82 | 0.79 (0.65–0.96)
S: 0.73; C: 0.89^*^ | S: 30,762; C: 30,966 Ages:45–75 % female: S: 51.7; C: 53 | 0.82 (0.68–0.99)
Funen (Denmark) Jorgenson 2002 ^134^ | S: 30,762; C: 30,966 Ages:45–75 % female: S: 51.7; C: 53 | S: 1.84 person yrs; C: 1.81 person yrs % of Dukes A: NR | 13 yrs (7 screening rounds) S: 0.72; C: 0.88 | 0.82 (0.69–0.97)
S: 0.83; C: 0.97^*^ | 0.85 (0.73–1.00)
Funen (Denmark) Kronborg 2004 ^131^ | S: 2.06 person yrs; C: 2.02 person yrs % of Dukes A: S: 18%; C: 11% | 17 yrs (9 screening rounds) S: 0.84; C: 1.00 | 0.84 (0.73–0.96)
S: 0.99; C: 1.10^*^ | 0.89(0.78–1.01)
Minnesota (USA) Mandel 1993 ^5^ | S: 15,587; C: 15,394 Ages: 50–80 % female S: 52.2; C: 52 | S: 23 persons; C: 26 persons % of Dukes A: S: 26.6%; C: 22.3% | 13 yrs NR (cumulative mortality) | 0.94 (0.68–1.31)
Minnesota (USA) Mandel 1999 ^135^ Mandel 2000 ^325^ | S: 33 persons; C: 39 persons | 18 yrs (5 years after end of screening period) NR (cumulative mortality) | 0.79 (0.62–0.97)
Goteborg 1996 (Sweden) Towler 1998 ^326^ | S: 34,144; C: 34,164 Ages: 60–64 % female: NR | NR | 8.3 yrs (6 yrs after 2 screening rounds) NR | 0.88 (0.69–1.12)
Goteborg 2005 (Sweden) Hewitson 2007 ^94^ | NR | 15.5yrs (13 years after 2 screening rounds) NR | 0.84 (0.67–0.99)

* deaths from CRC “including complications from treatment”.

S-screen group; C-control group

## Key Question 2a. What are the sensitivity and specificity of (1) colonoscopy, and (2) flexible sigmoidoscopy (FS) when used to screen for CRC in the community practice setting?

### Colonoscopy

Estimating the sensitivity and specificity for screening colonoscopy is challenging due to lack of a true gold standard. Also, most available studies have selected practitioners who were quite experienced and not necessarily representative of community practice. We considered studies that estimated sensitivity of colonoscopy in average-risk screening patients using tandem colonoscopy, or by analyzing the accuracy of initial colonoscopy in studies primarily examining the accuracy of CTC screening. No tandem colonoscopy studies evaluated average-risk populations, and most included only very experienced, as opposed to community-based, examiners. Thus, none of the tandem colonoscopy studies met our inclusion/exclusion criteria. Sensitivity estimates for colonoscopy were available from three CTC screening studies in average-risk screening patients that used segmental unblinding or second-look colonoscopy to evaluate lesions detected by CTC but missed on initial colonoscopy. While these studies all addressed average-risk patients and used an enhanced reference standard (second-look colonoscopy), they are limited in providing an accurate estimate of relative test performance and of community test performance for these two CRC screening approaches. First, the number of patients studied is small. Second, the designs compared the performance of larger number (between five and 50) of experienced colonoscopists to the performance of a smaller number (between two and six) of experienced radiologists using a range of technological approaches to CTC.

Sensitivity of screening colonoscopy. In a good-quality cross-sectional comparison, Pickhardt et al. ^136^ examined the sensitivity of same-day colonoscopy compared with CTC in 1,233 individuals in three medical centers in the United States. Subjects were asymptomatic adults (mean age 57.8 years) with no personal history of polyps, CRC, inflammatory bowel disease, or familial polyposis syndrome who were referred for colorectal cancer screening. CTC was conducted using fecal tagging with oral contrast. One of 6 trained radiologists using a commercially available CTC system interpreted the results. The radiologists viewed the colon initially using the 3D endoluminal fly-through view for detecting polyps (using 1.25–2.5 mm collimation), then used 2D images for confirmation and problem-solving. One of 17 experienced colonoscopists performed optical colonoscopy immediately after CTC interpretation using standard commercial video colonoscopes, with unblinding of the CTC results after examination of each segment of colon. For any suspected polyp seen on CTC that measured 5 mm or greater, which was not seen on the initial blinded colonoscopy, the colonoscopist closely reexamined that segment and could review the CTC images for guidance. The accuracy (represented by lower adenoma miss rates) of colonoscopy exceeded that of CTC for adenomas equal to or greater than 6 mm in size (10 vs. 14 percent), however miss rates were higher for colonoscopy than for CTC for larger adenomas ≥10 mm; and none of these differences were statistically significant. Sensitivity (per person detection rate) for colonoscopy was 92 percent (155/168) for patients with adenomas ≥ 6 mm in size, compared with 89 percent (149/168) for CTC; sensitivity of colonoscopy was 92 percent (75/82) for patients with an adenoma ≥ 8 mm in size, compared with 94 percent (77/82) for CTC; and sensitivity of colonoscopy was 88 percent (42/48) for patients with an adenoma ≥ 10 mm, compared with 94 percent (45/48) for CTC; none of these differences was statistically significant. Colonoscopy detected only one of two colorectal cancers (50 percent sensitivity), whereas CTC detected both colorectal cancers. The six radiologists reading the CTC had received training reading a minimum of 25 studies, and two had interpreted > 100 studies. The 17 colonoscopists were characterized as “experienced.”

A smaller fair-quality study by Kim et al. ^137^ compared various approaches to CTC in 96 individuals agreeing to participate in a screening study in Seoul, Korea, and also reported on the the detection of polyps by colonoscopy. Subjects were adults (mean age 54.8 years) with no history of polypectomy during the previous year, no positive FOBT or iron-deficiency anemia during the previous six months, no history of colorectal surgery, and no history of inflammatory bowel disease or familial adenomatous polyposis. Initial CTC readings were conducted by 1 of 2 radiologists with previous experience from at least 100 colonoscopy-proven CTC examinations. All images were 2 mm-slice thickness. One of the two radiologists initially viewed 2D transverse images, with 2D coronal and sagittal images and 3D endoluminal views as secondary techniques to better characterize any lesions. The other radiologist used a 3D-380 degree (virtual dissection) circular view for primary viewing, with 2D tranverse or multiplanar reconstruction images used to clarify any lesions found. Within 2 hours after CTC was completed, one of five board-certified gastroenterologists, each with 7–15 years of clinical experience, performed a colonoscopy with segmental unblinding to the CTC results. Colonoscopy detected 90 percent (35/39) of polyps ≥ 6 mm in size and all polyps 10 mm or larger (12/12). This study detected no CRC. Per-person detection (sensitivity) for colonoscopy was not directly reported.

A fair-quality study by Johnson et al ^138^ comparing various CTC approaches in 452 asymptomatic, average-risk patients at the Mayo Clinic also reported colonoscopy performance using retrospective review of videotaped colonoscopies. Subjects were adults (mean age 65 years.) with no personal history of gastrointestinal symptoms, inflammatory bowel disease, or familial adenomatous polyposis. Initial CTC readings were conducted by two of three experienced radiologists using one of two search methods: 2D or 3D. The primary 2D search method utilized a conventional 2D image display with 3D endoluminal problem solving, whereas the primary 3D search method utilized a 360-degree virtual dissection image display, which can display both multiplanar 2D and 3D perspective volume-rendered images for problem solving. Different slice thicknesses for CTC, 1.25 vs 2.5 mm, were also viewed within each subgroup. All three CTC reviewers had interpreted more than 1,000 colonoscopy-verified CTC examinations before this study, and had trained on at least 50 cases using 360-degree virtual dissection software before the study. Same-day index colonoscopy was performed (or supervised) by one of 50 experienced staff gastroenterologists and colorectal surgeons, blinded to the CTC results (and without segmental unblinding). Colonoscopy videotapes were reviewed if lesions of > 5 mm were identified on CTC but not during colonoscopy. Repeat colonoscopy was performed in six patients in whom a large (≥ 10 mm) missed lesion was deemed by consensus to have a high likelihood of being a true neoplasm. Colonoscopy detected 77 percent (20/26) of all neoplasms ≥ 10 mm in diameter. Four of the missed lesions were later determined to be adenocarcinomas. Colonoscopy therefore detected one of the five CRCs detected by CTC (20 percent). This study is limited since not all cases with a discrepancy between CTC and colonoscopy had a confirmatory examination. Further, the performance of three very experienced radiologists was compared to that of 50 experienced endoscopists (or more, since some examinations were only supervised and not performed by this group).

### Flexible Sigmoidoscopy (FS)

No studies reported the sensitivity and specificity of flexible sigmoidoscopy (FS) for CRC, advanced neoplasia, or adenomas by size, based on conducting both FS and colonoscopy in all average-risk screening patients. We therefore relied on three approaches to estimate accuracy of community FS. The first method is tandem FS studies that determine miss rates for the distal colon only, i.e. can apply only to lesions that lie within the reach of the sigmoidoscope. Although the reach of FS is variable, and may be better with current generation instruments, estimates are of a mean insertion depth ranging from approximately 40 up to 60 cm. ^139,^ ^140^ Another method for determining miss rates for the distal colon is to conduct repeated FS examination up to 3 years after a negative FS examination. While some lesions detected at three years may not have been present at the initial FS, given the natural history of adenoma progression, a maximum of three years for followup of negative lesions on an initial FS can fairly approximate miss rates. A final method was using studies of screening colonoscopy to simulate how screening FS, followed by colonoscopy examinations in those with findings on FS, would perform in detecting lesions in the entire colon. Researchers have used this approach to estimate the sensitivity of various FS protocols (i.e., FS with and without biopsy to determine referral for colonoscopy). The results from this FS protocol are estimates using findings of the initial FS and the results of that followup examination. This construct assumes 100 percent referral and compliance with followup colonoscopy for positive FS examinations. Sensitivity calculations from the studies reviewed here were for either a FS protocol using biopsy and referral for adenomas, or a FS protocol using visualization alone (without biopsy) and referral for all distal lesions. We calculated sensitivity of each type of FS protocol for all outcomes (CRC, adenomas by size, and advanced neoplasia), when possible.

Adenoma miss rates for flexible sigmoidoscopy. We found a single tandem FS study ^141^ describing adenoma miss rates, and two large, high-quality prospective studies that reported the incidence of advanced neoplasia and CRC in the distal colon during repeat FS 3 years after a negative screening FS exam. ^142,^ ^143^ All three FS studies were conducted in average-risk screening populations, predominantly involving people with no family history of colorectal cancer. Among 328 patients undergoing tandem FS in a community setting, the overall adenoma miss rate for polyps of any size was 20 percent. ^141^ The miss rate for large adenomas (≥ 10 mm in diameter) was 14.3 percent (2/14). The miss rate for adenomas 6 mm or greater was 19 percent (4/21). Both prospective followups of negative screening FS in average-risk populations (combined n=10,232) showed that approximately 0.8 percent of patients had advanced neoplasia in the distal colon viewed on a second FS conducted three years later. There were no adenocarcinomas detected in the distal colon three years after a negative screening examination.

Calculated sensitivity of flexible sigmoidoscopy with and without biopsy. The relationship of distal colon findings to proximal lesions has recently been studied in large cohorts of average-risk patients undergoing screening colonoscopy (see Table 4). ^58,^ ^60,^ ^61,^ ^144^ – ^146^ Three studies included up to 16 percent of patients with CRC in a first-degree relative, although many studies did not report this data. The distal examination of the colon (defined as the rectum, sigmoid, and descending colon up to, but not including, the splenic flexure) served as a surrogate for the reach of a FS examination. All investigators excluded patients who had gastrointestinal symptoms (e.g., abdominal pain, change in bowel habits, rectal bleeding) and patients with a history of colon disease (e.g., inflammatory bowel disease, polyps, or colorectal cancer). Four of the six studies ^58,^ ^60,^ ^61,^ ^144^ also excluded patients who had been screened with a FS or colonoscopy during the previous 5–10 years. Four of these six studies were conducted in the US. ^58,^ ^60,^ ^61,^ ^146^ The prevalence of CRC (0.1 to 1.0 percent) in a single examination with standard colonoscopy was fairly consistent among the five studies reporting this data. The prevalence of advanced neoplasms (defined as any adenoma 10 mm or larger, or with villous features, severe dysplasia, or carcinoma) anywhere in the colon varied more widely between the six studies, ranging from 2.4 to 10.5 percent. These lesions were more prevalent in studies of male veterans ^60^ and females from military medical centers. ^61^ The prevalence of proximal advanced neoplasia ranged from 0.9 percent to 4.1 percent. Isolated proximal advanced neoplasia (proximal neoplasias in those with no adenomas in the distal colon) varied from 0.8 percent to 3.2 percent among average-risk patients. It is important to bear in mind that, for all of these sensitivity estimates, using colonoscopic examination of the distal colon as a surrogate for FS may result in an overestimation of sensitivity due to superior bowel preparation for colonoscopy. And, examiner skill for colonoscopy may also vary from that for FS, particularly in the community setting.

Table 4 Sensitivity of flexible sigmoidoscopy protocol for advanced neoplasia

Study | Patient Characteristics | Overall polyp prevalence | Sensitivity of FS with biopsy for advanced neoplasia in the whole colon | Sensitivity of FS without biopsy for advanced neoplasia in the whole colon | Sensitivity of FS with biopsy for CRC in the whole colon | Sensitivity of FS without biopsy for CRC in the whole colon
Betes Ibanez 2004 ^144^ Spain Distal definition: descending & sigmoid colon, rectum | N: 2210 Age incl: >40; Mean age: 57.9 % Ethnic Origin:NR % female: 25.4% FH: NR | Any neoplasm: 28% Adv. neoplasm: 7% CRC: 0.5% | 85.3% (133/156) | NR | NR | NR
Ikeda 2000 ^145^ Japan Distal definition: splenic flexure, descending & sigmoid colon, rectum | N: 3131 Age incl: 48–57; Mean age: 61.2 % Ethnic Origin: [Japanese] % female: 0% FH: NR | Any neoplasm:25.9% Adv. neoplasm: 2.4% CRC: 0.6% | 73.7% (56/76) | NR | NR | NR
Anderson 2004 ^58^ USA Distal definition: descending & sigmoid colon, rectum | N: 1988 Age incl: >40; Mean age: 57.2 % Ethnic Origin:1.5% NW % female: 45.6% FH: 13.6% | Any neoplasm: 21.9% Adv. neoplasm: 10.2% CRC:0.4% | 73.8% (155/210) | NR | 62.5% (5/8) | NR
Imperiale 2003 ^146^ Imperiale 2000 ^59^ USA Distal definition: descending & sigmoid colon, rectum | N: 3025 (1994 subgroup) Age incl: ≥50; Mean age: 58.9 % Ethnic Origin: 90% white % female: 42% FH: NR | Any neoplasm: NR Adv. neoplasm: 6.0% CRC: NR | Total: 71.8% (130/181) Male: 70.0% (98/140) Female: 78.0% (32/41) | 76.8% (139/181) | 58.3%(7/12) | 75.0% (8/12)
Lieberman 2000 ^60^ USA Distal definition: descending & sigmoid colon, rectum | N: 3121 Age incl: 50–75; Mean age: 62.9 % Ethnic Origin: 16.4% NW % female: 3.2% FH: 13.9% | Any neoplasm: 37.5% Adv. neoplasm: 10.5% CRC: 1.0% | 81.7% (272/333) | 85.6% (285/333) | NR | NR
Distal definition: sigmoid colon, rectum | 71.2% (237/333) | 78.7% (262/333) | NR | NR
Schoenfeld 2005 ^61^ USA Distal definition: descending & sigmoid colon, rectum | N: 1463 Age incl: 40–79; Mean age: 58.9 % Ethnic Origin: 23% nonwhite % female: 100% FH: 15.7% | Any polyps: NR Any neoplasm: 20.4% Advanced neoplasm: 4.9% CRC: 0.1% | 50% (36/72) | NR | NR | NR
Distal definition: sigmoid colon, rectum | 34.7% (25/72) | NR | NR | NR

* This estimation of sensitivity is for flexible sigmoidoscopy with biopsy only

Simulated protocol for flexible sigmoidoscopy without biopsy. FS without biopsy is the traditional and lower-risk method of performing this test. The appropriate polyp size threshold for referral to colonoscopy is not well-established, and thus colonoscopy referral often follows detection of any lesion on FS. The Prostate, Lung, Colorectal, and Ovarian Cancer (PLCO) screening trial in the United States is currently examining CRC incidence and mortality rates after FS without biopsy, and pending results may also clarify how screening outcomes are related to different distal polyp size thresholds for referral. Our estimates of sensitivity for the FS without biopsy protocol assumed that a polyp of any size found on FS would prompt colonoscopy referral, which is the same protocol as for the PLCO trial. ^147^

Only two screening colonoscopy studies (in three publications) provided data allowing the calculation of the sensitivity of FS without biopsy in average-risk adults. ^59,^ ^60,^ ^146^ Sensitivity for CRC in the entire colon (75 percent) could be estimated from a single study of 1994 adults with a total of 12 CRCs detected, ^59^ while sensitivity for advanced neoplasia in the entire colon ranged from 76.8 to 85.6 percent in two studies of 6146 adults with a total of 514 advanced neoplasias detected. ^60,^ ^146^

Simulated protocol for flexible sigmoidoscopy with biopsy. FS with biopsy is a protocol used in three FS trials whose CRC incidence and mortality outcomes are pending. ^81^ – ^83^ The criteria for colonoscopy referral in two of these studies is the FS detection of any single adenoma ≥10 mm, with tubulovillous or villous histology, severe dysplasia, or malignancy, or the detection of three or more adenomas of any size or histology. ^82,^ ^83^ We used these same criteria to calculate the sensitivity of FS with biopsy for six colonoscopy screening studies in a total of 14,938 average-risk patients. The sensitivity of FS with biopsy for CRC in the entire colon ranges from 58.3 to 62.5 percent, based on two studies in 3982 average-risk adults that detected a total of 20 cancers. ^58,^ ^59^ Sensitivity of FS with biopsy for advanced neoplasia (1,028 lesions throughout the entire colon) in six studies ranged from 71.8 to 85.3 percent, with an outlier study reporting 50 percent sensitivity in a sample of women examined at military medical centers. ^61^ The one other study that reported sex-specific sensitivity estimates suggested that FS was equally or more sensitive for advanced colonic neoplasia (32/41 lesions in the entire colon) in women (78 percent), compared with men (70 percent, 98/140 lesions). ^146^ These studies defined the distal colon reached by FS as up to the splenic flexure. As expected, using a more limited definition of the distal colon that would be reached by FS (up to the junction of the sigmoid and descending colons) ^61^ resulted in a decrease in sensitivity for advanced neoplasia in women (from 50 to 34 percent) and men (from 82 to 71 percent) ^60,^ ^61^ (see Table 4).

## Key Question 2b. What are the test performance characteristics of (1) CT colonography (CTC) and (2) fecal screening tests (e.g., high-sensitivity guaiac fecal occult blood testing (HS-FOBT), fecal immunological test (FIT), or fecal DNA tests) for CRC screening as compared to an acceptable reference standard?

### CT Colonography (CTC)

Recent systematic reviews ^116^ – ^121^ have identified 40 studies comparing CTC using a variety of imaging approaches and scanner types with a reference standard. These reviews summarized data across a large range of technological approaches to CTC and with varying patient populations, reference standards, study designs, and outcomes. The most comprehensive of these current reviews by Mulhall evaluated 33 prospective studies in 6393 adult patients comparing CTC (that met a minimum level for quality and technological sophistication) to colonoscopy or surgery. ^116^ Only four studies from this review, however, addressed average-risk patients. ^136,^ ^148^ – ^150^ While we identified no additional studies in average-risk patients after examining other systematic reviews, we did locate three additional studies comparing different CTC approaches (2D imaging and 3D imaging) to colonoscopy in average-risk patients. ^137,^ ^138,^ ^151^ We first discuss the Mulhall review to provide a context for considering the more limited research examining CTC screening in average-risk patients.

The reported CTC sensitivity varied widely among the 33 studies conducted in all patient populations in Mulhall's review. ^116^ Per-patient sensitivity ranged from 30 percent to 100 percent for polyps 6 mm or greater in diameter. These data could not be pooled due to significant between-study heterogeneity that persisted even within size-specific polyp strata (6–9 mm, ≥ 10 mm). Per-patient specificity estimates were more homogeneous across studies and pooled estimates varied significantly with polyp size. Specificity for polyps greater than 9 mm was 97 percent (CI: 96, 97), and was significantly better than for polyps 6–9 mm (93 percent, CI: 91, 95) and polyps < 6 mm (91 percent, CI: 89, 95). Meta-regression suggested that the CTC technology impacted CTC sensitivity. Sensitivity decreased 4.9 percent (CI: 0.8, 7.1) for every 1-mm increase in the width of the CTC slice thickness (based on collimation setting). Sensitivity was higher (95 percent, CI: 92, 99) and homogeneous (I^2^ = 40 percent) in studies using multi-detector scanners, compared with nonhomogeneous estimates from studies using single-detector scanners. Similarly, studies that used standard two-dimensional (2D), with concomitant three-dimensional (3D) imaging, rather than 2D imaging with 3D imaging only for confirmation, were more sensitive and homogeneous in their findings. Fly-through (3D) technology was applied in only two studies, but had the highest sensitivity (99 percent, CI: 95,100).

We located six fair- or good-quality cross-sectional studies ^136^ – ^138,^ ^148^ – ^150^ that examined a total of 1937 average-risk patients screened for colorectal cancer with both CTC and colonoscopy on the same day. Three of these studies are not discussed here because: two of these studies involved very small samples (less than 50 patients) and used older, less consistent single detector technology; ^148,^ ^150^ the other study provided accuracy data that reflects a very small number (n=16) of polyps larger than 6 mm, and researchers used a questionable approach of assuming that CTC-located lesions not found on colonoscopy were false positives due to residual fecal materials. ^149^ These studies are included in Appendix D. In the three remaining studies, 40 to 45 percent of participants were women. ^136^ – ^138^ Most participants were aged 50 to 79 years. Information on race/ethnicity was provided in one study that included 15 percent Nonwhites, ^138^ and one study was conducted in Korea. ^137^ These three studies also provided data on sensitivity of colonoscopy (KQ2a). ^136^ – ^138^

A good-quality study conducted by Pickhardt represents the largest single study on the accuracy of CTC screening compared with colonoscopy in average risk patients that has been published to date, and the only one whose primary purpose was to address this question. This study enrolled 1233 average-risk patients (41 percent female; ages 50 to 79 years; two percent under age 50 with a positive family history for CRC) and compared same-day colonoscopy with CTC using 3D fly-through endoluminal display, fecal tagging, and contrast-based luminal fluid opacification. ^136^ Trained radiologists conducted all readings. Seventeen experienced colonoscopists initially blinded to the CTC results conducted the colonoscopies. Segmental unblinding of results from the CTC permitted colonoscopists to recheck CTC findings that were not located on first-pass colonoscopy. This also allowed researchers to clearly separate false-positive CTC results from false-negative colonoscopy results. About half of the patients (50.4 percent) had a polyp and 13.6 percent had adenomas. Two patients had adenocarcinomas, 3.9 percent had large adenomas (10 mm or greater in diameter), and 13.6 percent had adenomas 6 mm or greater. Per-patient CTC sensitivity for adenomas did not differ by lesion size (89 to 94 percent) and was not significantly different between CTC and colonoscopy (see Table 5). However, one of two carcinomas was missed on colonoscopy. This study's sensitivity estimates might be considered best estimates due to the use of 3D fly-through CT technology with fecal tagging and luminal fluid opacification, and the use of a limited number (six) of reasonably experienced radiologist readers. Per-patient CTC specificity varied significantly by lesion size, with significantly worse per-patient specificity (79.6 percent) for lesions 6 mm or greater, compared with 96 percent specificity for lesions 10 mm or greater. Specificity estimates may be affected by two influential study factors: 1) CTC specificity could be underestimated due to the conservative assumption that polyps identified on CTC were false positives if they matched only with a nonadenomatous polyp; 2) CTC specificity could be overestimated due to the use of contrast materials to allow fecal tagging and residual fluid opacification. While these techniques are widely accepted ^138^ and are used in large screening studies, it is not clear if they are common in community practice. Depending on the referral threshold for CTC findings triggering a colonoscopy referral, as few as one out of 13 patients undergoing CTC would be referred based on a polyp of 10 mm diameter or greater, compared with as many as one out of three patients for a polyp of 6 mm diameter or greater. Considering sensitivity at the lesion level, the per-polyp sensitivity of CTC and colonoscopy for advanced neoplasia did not significantly differ. In a related publication, the sensitivity for flat adenomas 6 mm or larger (82.8 percent) was reported to be similar to the sensitivity for polypoid adenomas 6 mm or larger (86.2 percent), although this determination was based on a total of 29 flat adenomas 6 mm or greater, with flat polyps found in 52/1233 persons (4.9 percent). ^152^

Table 5 Sensitivity and specificity of CT colonography (CTC)

| Reference standard | Sensitivity per-patient | Specificity per-patient | Total positivity Rate | Referral Rate for colonoscopy
3D measurements
Pickhardt 2003 ^136^ (n=1233) | Segmentally unblinded optical colonoscopy; oral contrast; fecal tagging; 1.25–2.5 mm collimation.
adenoma ≥ 10 mm | Segmentally unblinded optical colonoscopy; oral contrast; fecal tagging; 1.25–2.5 mm collimation. | 93.8% [82.8–98.7] | 96.0% [94.8–97.1] | 7.5% [6.1–9.1] | 1 out of every 13 screened
adenoma ≥ 8 mm | Segmentally unblinded optical colonoscopy; oral contrast; fecal tagging; 1.25–2.5 mm collimation. | 93.9% [86.3–98.0] | 92.2% [90.5–93.7] | 13.5% [11.7–15.6] | 1 out of every 7 screened
adenoma ≥ 6 mm | 88.7% [82.9–93.1] | 79.6% [77.0–82.0] | 29.7% [27.1–32.3] | 1 out of every 3 screened
Kim 2007 ^137^ (n=96) | Segmentally unblinded optical colonoscopy; IV contrast; no fecal tagging; 2 mm collimation.
polyp ≥ 10 mm | Segmentally unblinded optical colonoscopy; IV contrast; no fecal tagging; 2 mm collimation. | 100% [100–100] (calc) | 100% [100–100] (calc) | 9.9% [5.7–14.1] (calc) | 1 out of every 10 screened
polyp ≥ 8 mm | Segmentally unblinded optical colonoscopy; IV contrast; no fecal tagging; 2 mm collimation. | 88.5% [76.2–100] (calc) | 98.5% [96.2–100] (calc) | 13.5% [8.7–18.4] (calc) | 1 out of every 7 screened
polyp ≥ 6 mm | 75% [62.2–87.8] (calc) | 94% [90.1–97.8] (calc) | 21.9% [16.0–27.7] (calc) | 1 out of every 5 screened
Johnson 2007 ^138^ (n=452) | Video optical colonoscopy; no contrast; no fecal tagging; 1.25 mm collimation presented here.
adenoma ≥ 10 mm (1.25mm slice) | Video optical colonoscopy; no contrast; no fecal tagging; 1.25 mm collimation presented here. | 73% [56.0–90.1] (calc) | 98% [96.2–99.1] (calc) | 3.2% [2.0–4.3] (calc) | Not calculated*
adenoma 6–9 mm (1.25mm slice) | 60% [42.5–77.5] (calc) | 94% [92.0–96.5] (calc) | 4.6% [3.3–6.0] (calc) | Not calculated*
2D measurements
Pickhardt 2007 ^151^ (n=730) | Segmentally unblinded optical colonoscopy; oral contrast; fecal tagging; 1.25–2.5 mm collimation.
polyp ≥ 10 mm | Segmentally unblinded optical colonoscopy; oral contrast; fecal tagging; 1.25–2.5 mm collimation. | 63.4% [48.7–78.2] | 98.1% [97.1–99.1] | 5.3% (calc) | 1 out of every 19 screened
polyp ≥ 6 mm | 43.0% [35.0–50.9] | 95.2% [93.4–96.9] | 12.6% (calc) | 1 out of every 8 screened
Kim 2007 ^137^ (n=96) | Segmentally unblinded optical colonoscopy; IV contrast; no fecal tagging; 2 mm collimation.
polyp ≥ 10 mm | Segmentally unblinded optical colonoscopy; IV contrast; no fecal tagging; 2 mm collimation. | 100% [100–100] (calc) | 99.5% [100–100] (calc) | 9.9% [5.7–14.1] (calc) | 1 out of every 10 screened
polyp ≥ 8 mm | Segmentally unblinded optical colonoscopy; IV contrast; no fecal tagging; 2 mm collimation. | 92% [82.1–102.6] (calc) | 98.5% [96.2–100.2] (calc) | 14.1% [9.1–19.0] (calc) | 1 out of every 7 screened
polyp ≥ 6 mm | 61.5% [47.0–75.8] (calc) | 90% [85.0–94.7] (calc) | 21.9% [16.0–27.7] (calc) | 1 out of every 5 screened
Johnson 2007 ^138^ (n=452) | Video optical colonoscopy; no contrast; no fecal tagging; 1.25 mm collimation presented here.
adenoma ≥ 10 mm (1.25mm slice) | Video optical colonoscopy; no contrast; no fecal tagging; 1.25 mm collimation presented here. | 76% [59.3–92.7] (calc) | 98% [96.8–99.4] (calc) | 3.0% [1.9–4.1] (calc) | Not calculated*
adenoma 6–9 mm (1.25mm slice) | 53% [35.5–71.2] (calc) | 95% [93.2–97.3] (calc) | 4.0% [2.7–5.2] (calc) | Not calculated*

* Polyp prevalence significantly different than those reported in similar studies.

There is currently debate about the relative accuracy of primary 2D compared with primary 3D methods for displaying and reviewing CTC screening results. ^153^ While both visualization approaches are generally employed in current CTC reading, the difference lies in which approach is used for primary polyp detection (primary 2D or 3D approach), and which is used for confirmation or problem solving. ^151^ Two studies compared sensitivity between these approaches in patients who received no oral contrast, and therefore did not have fecal tagging.

In a fair-quality retrospective study, primary 2D and primary 3D virtual dissection CTC technology using a multidetector scanner with IV contrast, but without oral contrast, were compared with same-day colonoscopy in 96 patients referred for screening colonoscopy. ^137^ Twenty-three percent of patients had polyps ≥ 6 mm. Two very experienced radiologists read the studies on the same patients, separated by 2 months between 2D and 3D viewings. Using either approach, both readers had 100 percent sensitivity and 99–100 percent specificity for large polyps (10 mm or greater). For lesions 8 mm or larger, one lesion was missed on 3D by one reader (resulting in 85 percent sensitivity instead of 92 percent sensitivity for 3D CTC), but 2D and 3D sensitivity were otherwise the same, as were specificity (98–99 percent). Sensitivity of 3D CTC appeared to be better for lesions 6 mm or larger (73–77 percent for 3D CTC vs. 59–64 percent for 2D CTC), but these differences reflect detecting three fewer lesions, showing the imprecision associated with small numbers. For one reader, specificity for lesions 6 mm or larger appeared lower for 2D than for 3D CTC (specificity estimates 89 to 99 percent), but small numbers again affected the precision of these estimates.

In a fair-quality study, primary 2D and primary 3D virtual dissection CTC technology using a multidetector scanner without contrast were compared with same-day colonoscopy in 452 asymptomatic patients referred for screening colonoscopy. ^138^ Investigators also examined the impact of CTC slice thickness (1.25 vs. 2.5 mm) on sensitivity and specificity. They also reviewed differences between very experienced readers. A little over twelve percent of patients had one or more adenomatous lesions—5.8 percent with adenomas 10 mm or larger in size and 6.6 percent with adenomas 6–9 mm. Limited power suggested no significant difference in test performance for 1.25 vs. 2.5 mm collimation, and we report here the most sensitive (1.25 mm) test results. When averaged across readers looking at different sets of randomly assigned patient images, per-patient sensitivity of 2D or 3D reading for adenomas 10 mm or greater was 76 percent and 73 percent, respectively. Sensitivity was much higher (95 percent) when 2D and 3D reading results were combined. Compared with the sensitivity for larger adenomas, lower sensitivity was seen for adenomas 6–9 mm using 2D (53 percent) and 3D (60 percent); sensitivity for smaller adenomas also improved if the two approaches were combined (71 percent). Specificity was similarly good between 2D and 3D approaches for large adenomas (98–99 percent) and for smaller (6–9 mm) adenomas (above 94–95 percent), with lower overall specificity for smaller adenomas. These results were achieved without the use of oral contrast for fecal tagging. Due to this study's primary aims of comparing readers and different CTC technical parameters, results were reported for subsets of the total patients and result in small numbers, affecting the precision of these estimates of test accuracy.

Pickhardt, et al. have recently published a fair-to-good quality reanalysis of 730 of the original 1233 cases from their study of a primary 3D endoluminal fly-through approach. This study compared the sensitivity of this approach with that of more experienced CTC readers using primarily 2D methods, with 3D displays reserved for problem solving. ^151^ Per-patient sensitivity for large adenomas (10 mm or greater) in the subset of 730 patients using primary 2D CTC was 81 percent, compared with 94 percent for 3D CTC in the entire cohort. Including smaller adenomas (6 mm or greater), 2D CTC sensitivity was markedly reduced (49 percent), compared with 3D CTC (89 percent). Specificity for 2D CTC was the same as 3D CTC for large polyps (97 percent compared with 98 percent, respectively), but higher for smaller polyps (95 percent for 2D CTC compared with 85 percent for 3D CTC). A strength of this study was using one software system (Viatronix) for both approaches, the sample size, and the use of fecal tagging which likely improved the specificity of 2D. Study limitations include the comparison of the subset for 2D to the entire cohort for 3D and possible conflicts resulting from the author serving as a consultant to the manufacturer.

At the time of our review, results from a large CTC study had been presented but not yet published. These preliminary results from the American College of Radiology Imaging Network (ACRIN) National CT Colonography Trial, an NIH-funded multicenter study of 2,531 average-risk individuals, examining the accuracy of CTC are described in the Discussion section on CTC.

### Fecal Screening Tests

Fecal screening test summary. Recent systematic reviews ^122,^ ^123^ identified more than 130 studies evaluating the analytic and clinical test performance of 18 fecal occult blood tests (FOBTs)—-17 fecal immunochemical tests (FITs) and one high-sensitivity guaic FOBT (Hemoccult Sensa)—-that were developed after Hemoccult and Hemoccult II. We further identified 18 additional published studies through searching. We excluded case-control studies of screening accuracy, since these consistently reported higher sensitivity for FOBTs than did cohort studies. ^122^ Case-control studies have been shown to overestimate sensitivity as a design-related source of bias. ^154^ Among cohort studies we evaluated, very few compared fecal screening test results to a valid reference standard (e.g., colonoscopy) or to an acceptable reference standard (e.g., colonoscopy for positives and systematic followup for negatives). To represent test performance in average-risk screening populations, we retained studies including participants enrolled from mass screening programs (community-, worksite-, or population-based) or non-CRC-focused health appraisal programs. Given the relatively few number of cohort studies available for individual tests, we also retained several studies with a higher potential for selectivity (e.g., not clearly representing average-risk screening participants, e.g. screening programs at cancer centers, doctor-initiated screening activities, and medical checkups for colorectal cancer).

Recent systematic reviews ^124,^ ^126,^ ^155^ have identified 24 studies evaluating the analytic test performance of fecal DNA tests in selected groups of patients with colorectal cancer, adenomas, hyperplastic polyps, other GI diseases, or normal colonoscopy findings. We identified one additional published analytic test performance study. ^156^ None of these studies were cohort studies conducted in average-risk patients undergoing screening. We found two clinical studies providing information on fecal DNA testing for CRC screening. ^157,^ ^158^

High-sensitivity guaiac testing. None of the cohort studies we found examined the test performance characteristics of high-sensitivity guaiac testing (Hemoccult Sensa) by ensuring that all participants received the same reference standard test. Two at least fair-quality cohort studies in average-risk screening populations from the same managed care institution in the United States evaluated Hemoccult Sensa in a total of 13,945 average-risk adults aged 50 years and older. These studies used endoscopy for those testing positive and medical record/tumor registry followup over 2 years for those testing negative (supplemented by FS in those with negative FOBTs in the second study) ^159,^ ^160^ (See Table 6). The first study compared four FOBT screening strategies: high-sensitivity guaiac (Hemoccult Sensa), nonrehydrated Hemoccult II, FIT alone (using HemeSelect), and a Hemoccult Sensa/HemeSelect screening sequence in 8104 adults (47 percent Nonwhite; 59 percent female, 31 percent aged 70 years or older) who were advised to undertake dietary and medication restriction prior to screening. ^160^ Hemoccult Sensa had a much higher test positivity rate (13.6 percent) than Hemoccult II (2.5 percent), which improved sensitivity for CRC (79.4 percent compared with 37.1 percent), but reduced specificity (86.7 percent vs. 97.7 percent). Performance for FIT testing is discussed in the following section. The sensitivity of Hemoccult Sensa was likely overestimated, and the specificity was likely underestimated, since not all participants received a colonoscopy. Followup of some screen-positive patients was completed through FS, which would not detect proximal lesions and thereby underestimates specificity. The screen-negative patients were followed through medical records, which would overestimate sensitivity. In a recently published followup study of 5841 average-risk screening patients (26 percent Nonwhite, 53 percent female, 11 percent aged 70 years and older), Hemoccult Sensa was compared to a fecal immunochemical test (FlexSure), alone or in combination with Hemoccult Sensa. The screen-positive patients received colonoscopy, while test negative patients received FS. ^159^ Hemoccult Sensa had the highest test positivity (10 percent) of the three fecal occult blood testing approaches, with possibly lower sensitivity for left-sided (distal) CRC than the fecal immunochemical test (FIT) alone (64.3 percent sensitivity compared with 81.8 percent, estimates not statistically different). Hemoccult Sensa also had a clearly lower specificity for left-sided CRC (90.1 percent compared with 96.9 percent). A combination Hemoccult Sensa/FlexSure screening approach, where the FIT was developed only if the guaiac-based test was positive, had identical sensitivity and better specificity than Hemoccult Sensa alone (98.1 percent compared with 90.1 percent). Absolute sensitivity or specificity for whole-colon CRC cannot be inferred from these estimates, although the authors' provision of estimates for left-sided lesions is reliable.

Table 6 Fecal immunochemical test summary table*

| Gold Standard | Cut off/Other FOBT tested | Fecal sample | Test positivity rate | Sensitivity | Specificity | FDA approved | US market
Magstream
Morikawa ^163^ n=21,805 Fair | Colonoscopy all patients | 20 ng/ml | 1-day | 5.6% | CRC: 65.8% | CRC: 94.6% | No | No
Morikawa ^163^ n=21,805 Fair | Colonoscopy all patients | 20 ng/ml | 1-day | 5.6% | AdvNeo: 27.1% | AdvNeo: 95.1% | No | No
Aden ≥ 10mm: 20.0% | Aden ≥ 10mm: NR
Launoy ^166^ n=7421 Fair | Registry followup-screen negative; Colonoscopy-screen positive | >20 ng/ml | 2-day | 5.8% | CRC: 85% | CRC: 94% | No | No
Launoy ^166^ n=7421 Fair | Registry followup-screen negative; Colonoscopy-screen positive
Launoy ^166^ n=7421 Fair | Registry followup-screen negative; Colonoscopy-screen positive | AdvNeo: NR | AdvNeo: NR
Launoy ^166^ n=7421 Fair | Registry followup-screen negative; Colonoscopy-screen positive
Launoy ^166^ n=7421 Fair | Registry followup-screen negative; Colonoscopy-screen positive | >50 ng/ml | | 3.1% | CRC: 67.8% | CRC: 97%
AdvNeo: NR | AdvNeo: NR
>75 ng/ml | | 2.0% | CRC: 61% | CRC: 98%
AdvNeo: NR | AdvNeo: NR
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive | HemeSelect (Magstream) | 3-day | 5.9% | CRC: 68.8% | CRC: 94.4% | Yes | No
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive | Polyp ≥ 10mm: 66.7% | Polyp ≥ 10mm: 95.2%
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive | HO Sensa | | 13.6% | CRC: 79.4% | CRC: 86.7% | Yes | Yes
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive
Allison ^160^ n=8104 Fair | Registry followup-screen negative; Colonoscopy-screen positive | Polyp ≥ 10mm: 68.6% | Polyp ≥ 10mm: 87.5%
HO Sensa/HemeSelect | | 3.0% | CRC: 65.6% | CRC: 97.3%
Polyp ≥ 10mm: 50.0% | Polyp ≥ 10mm: 97.9%
Hemoccult II | | 2.5% | CRC: 37.1% | CRC: 97.7% | Yes | Yes
Polyp ≥ 10mm: 30.8% | Polyp ≥ 10mm: 98.1%
OC-Hemodia
Cheng ^161^ n=7411 Fair | Colonoscopy all patients | | 3-day | 9.2% | CRC: 87.5% | CRC: 91.0% | No | No
AdvNeo: 48.4% | AdvNeo: 91.3%
Itoh ^165^ n=27,860 Fair | Registry followup-screen negative; Colonoscopy-screen positive | | 1-day | 5.3% | CRC: 86.5% | CRC: 94.9% | No | No
Levi ^327^ Family History Subset (n=80) Fair | Colonoscopy all patients | | 3-day | 18.8% | CRC: 66.7% | CRC: 83.1% | No | No
AdvNeo: 55.6% | AdvNeo: 91.9%
FlexSure OBT
Allison† ^159^ n=5841 Good | Colonoscopy-screen positive or FS - screen negative | FlexSure | 3-day | 3.2% | CRC: 81.8% | CRC: 96.9% | Yes | Yes
Allison† ^159^ n=5841 Good | Colonoscopy-screen positive or FS - screen negative
Allison† ^159^ n=5841 Good | Colonoscopy-screen positive or FS - screen negative | Aden ≥ 10mm: 29.5% | Aden ≥ 10mm: 97.3%
Allison† ^159^ n=5841 Good | Colonoscopy-screen positive or FS - screen negative
Allison† ^159^ n=5841 Good | Colonoscopy-screen positive or FS - screen negative | HOSensa | | 10.1% | CRC: 64.3% | CRC: 90.1% | Yes | Yes
Aden ≥ 10mm: 41.3% | Aden ≥ 10mm: 90.6%
FlexSure/ HOSensa | | 2.1% | CRC: 64.3% | CRC: 98.1%
Aden ≥ 10mm: 22.8% | Aden ≥ 10mm: 98.4%
Monohaem
Nakama ^169^ n=4611 Fair | Colonoscopy all patients | | 1-day | NR | CRC: 55.6% | CRC & Aden: 97.1% | Yes | No
Nakama ^169^ n=4611 Fair | Colonoscopy all patients
Nakama ^169^ n=4611 Fair | Colonoscopy all patients | | Aden: 30.1%
Nakama ^169^ n=4611 Fair | Colonoscopy all patients
Nakama ^169^ n=4611 Fair | Colonoscopy all patients | | 2-day | NR | CRC: 83.3% | CRC& Aden: 96.0%
Aden: 50.7%
3-day | NR | CRC: 88.9% | CRC & Aden: 93.9%
Aden: 54.8%
Nakama* ^167^ n=3365 Fair | Registry followup-screen negative; Colonoscopy-screen positive | 1 yr followup | 1-day | 4.7% | CRC: 90.9% | CRC: 95.6% | Yes | No
Nakama* ^167^ n=3365 Fair | Registry followup-screen negative; Colonoscopy-screen positive | 2 yr followup | 1-day | 4.7% | CRC: 83.3% | | Yes | No
3 yr followup | CRC: 71.4%

* Sensitivity and specificity of small adenomas or polyps of unknown size found in full evidence table.

† Left-sided cancers only.

CRC-colorectal cancer; NR-not reported; AdvNeo-advanced neoplasia; Aden-adenoma

Fecal immunochemical tests (FIT). We identified 12 types of FITs representing 20 different proprietary names. Differences in test methodology do not allow these tests to be analyzed as a class, although some tests are part of the same developmental test sequence.

FITs vary in terms of their FDA approval status and their availability in the United States (see Appendix D Table 5). We found admissible studies (cohort design, average-risk population, acceptable reference standard) that evaluated the test performance characteristics of five different FITs (OC-Hemodia, FlexSure OBT [now called Hemoccult ICT], Monohaem, Magstream, and HemeSelect). HemeSelect, Immudia HemSP, and Magstream are related tests, with more current versions allowing quantitative results from an automated reader. HemeSelect, Monohaem, and FlexSure OBT are FDA approved. Only FlexSure OBT (Hemoccult ICT) appears to currently be marketed in the US (see Table 6). We found no eligible studies evaluating other FITs—InSure (Inform is the same test), Quickvue, and Hemosure—that are both FDA approved and currently on the US market.

Nine fair- or good-quality cohort studies in a total of 86,498 average-risk patients evaluated FIT using a valid reference standard (colonoscopy in all patients regardless of FIT results), ^159,^ ^161^ – ^164^ or an acceptable reference standard (followup of negatives as a substitute for conducting endoscopy in all participants). ^160,^ ^165^ – ^167^ (See Table 6) We did not include an additional study ^168^ that used an identical screening population as an included study, and thus appeared redundant. ^161^

Since optimal test performance for one of the FITs (Monohaem) was achieved with a 2-day specimen collection, compared with a 1-day or 3-day approach, we preferentially describe 2-day collection results when available.

We found the largest evidence base (3 fair-quality studies in 37,330 persons) for the Magstream-related FITs. ^160,^ ^163,^ ^166^ One study was conducted in a representative US primary care population. ^160^ Two of these studies evaluated Magstream or Immudia-SP and provided quantitative (as opposed to qualitative) test results from an automated reader. ^163,^ ^166^ Only one study, done in 7421 average-risk adults, ^166^ provided quantitative results across a range of cutpoints for the 2-day sampling approach, however, and this study used observation for development of CRC for those testing negative as the reference standard (instead of colonoscopy). As such, this study could provide test accuracy for CRC only and may overestimate sensitivity and underestimate specificity. In this study, test positivity for Magstream ranged from a high of 5.8 percent at 20 ng/ml to a low of 2.0 percent at 75 ng/ml, with higher sensitivity for CRC (85 percent) at the 20 ng/ml cutpoint and as low as 61 percent at the 75 ng/ml cutpoint. Specificity was reasonable at the lower cutpoint (94 percent) and better at the higher cutpoint (98 percent). Sensitivity for advanced neoplasia in a separate study employing colonoscopic evaluation of all patients was 27 percent (based on a single day sample), with a specificity of 95 percent. ^163^ When directly compared to Hemoccult II, qualitative results from HemeSelect had a higher sensitivity for CRC (69 percent compared to 37 percent for Hemoccult II) and a lower specificity (94 percent compared with 98 percent). ^160^ Using Hemoccult Sensa/HemeSelect in sequence achieved virtually the same sensitivity for CRC as HemeSelect alone, thought it had much better specificity (97 percent). The specificity of this sequence was comparable to the specificity of Hemoccult II.

Three fair-quality studies evaluated OC-Hemodia in 35,171 average-risk patients with unknown applicability to the US population, and with some differences in study design from already-described studies. ^161,^ ^162,^ ^165^ One study in 27,680 persons used a 1-day sampling scheme, but also used followup (rather than endoscopy) to estimate false negatives from FIT screening. ^165^ Test positivity was lower for the 1-day sampling (5.3 percent) than for the 3-day sampling approaches (9.2 to 18.8 percent, although this latter estimate is based on small numbers). Sensitivity for CRC in the 1-day sampling approach (86.5 percent) was comparable to the larger study using 3-day sampling (87.5 percent). ^161^ The 1-day sample had a higher specificity (94.9 percent compared with 91.0 percent). Sensitivity for advanced neoplasia in the study employing colonoscopic evaluation of all patients was 48 percent (based on a 3-day sample), with a specificity of 91 percent. ^161^ Estimates for OC-Hemodia accuracy in the small subgroup of persons who met our criteria for average risk (n=80) from a larger study of diagnostic colonoscopy were imprecise, due to small numbers. ^162^

Two fair-quality studies evaluated Monohaem in 7976 average-risk Japanese patients. In the largest study (n=4611) using colonoscopy for the entire screening population, sensitivity for CRC for a 2-day sample was 83 percent and specificity was 96 percent. Sensitivity for advanced neoplasia was 51 percent. ^169^ In a separate study by the same group, much higher sensitivity was reported using followup of negatives, illustrating how this method may inflate sensitivity estimates. ^167^

A single good-quality prospective study in 5841 screening patients aged 50 and older (26 percent Nonwhite, 53 percent female, 11 percent aged 70 years and older) evaluated FlexSure OBT (now Hemoccult ICT) and sequential screening using Hemoccult Sensa followed by FlexSure OBT for any positives. This study was conducted in a real-world managed care setting in the US. ^159^ FOBT-positives received a colonoscopy and FOBT-negatives were referred for FS (with about 80 percent completion of endoscopy), with 2-year followup for CRC detection. Fourteen cancers were detected along with 128 large adenomas. Test positivity was slightly higher for FlexSure (3.2 percent) than for the combination (2.1 percent). Both rates were much lower than Hemoccult Sensa alone (10.1 percent). FlexSure had similar sensitivity for distal CRC (82 percent) and for large distal adenomas (30 percent) as Hemoccult Sensa and the combination test power for differences was limited due to small numbers. The combination test had the best specificity for either outcome, with FlexSure a close second (96.9 percent and 98.1 percent for CRC, respectively). While absolute sensitivity or specificity for whole-colon CRC cannot be inferred from these estimates, these estimates for left-sided (distal) lesions are reliable.

Fecal DNA testing. Applicable fecal DNA screening studies are limited to one fair-quality large cohort study using a multitarget fecal DNA panel test (the pre-commercial version of Pre-Gen Plus™, version 1.0), in 4404 average-risk patients undergoing colonoscopy, ^158^ and a smaller cohort study of a test for a single mutation of the K-ras gene. ^157^ In the best study available, researchers compared a one-time multitarget fecal DNA panel (PreGen Plust ™, version 1.0) with 3-card non-rehydrated Hemoccult II in 4404 average-risk asymptomatic patients who all underwent colonoscopy. ^158^ The study only provides data on a one-time screening approach, rather than a screening program. Of the 5486 enrolled participants, 1082 (19.7 percent) did not complete some aspect of the testing: 770 (71 percent) did not complete the colonoscopy, 641 (59 percent) did not provide an adequate fecal DNA sample, and 426 (43 percent) did not provide an adequate Hemoccult II sample. A higher percentage of incomplete samples for fecal DNA testing, which required at minimum a 30g stool sample with receipt within 72 hours, compared with Hemoccult II, which required a sampling strategy from multiple stools, may signal differences in feasibility or acceptability to patients. From the 4404 that were fully tested, a subset (n=2507) with a mean age of 69.5 years, 44.5 percent male, 87 percent white, 13.9 percent positive family history, were selected for fecal DNA testing based on results of the colonoscopy and histopathology. The multitarget fecal DNA test, PreGen Plus ™, tested for 21 DNA mutations in the K-ras, APC, and p53 genes, along with markers for miscrosatellite-instability and long DNA.

Patients who received multitarget fecal DNA testing included those with invasive adenocarcinomas (n=31) or advanced adenoma (n=403), one rectal carcinoid tumor, one cloacogenic tumor, and a randomly selected subgroup with minor (n=648) or no (n=1423) detected polyps. Among this subset, 8.2 percent were test-positive on the fecal DNA panel and 5.8 percent had a positive Hemoccult II. One-time fecal DNA testing was more sensitive for adenocarcinoma than Hemoccult II (51.6 percent, [CI: 34.8, 68.0] and 12.9 percent [CI: 5.1, 28.9], respectively). Sensitivity for advanced adenomas was similarly poor for fecal DNA testing (15.1 percent, [CI: 12.0, 19.0] and for Hemoccult II (10.7 percent, [CI: 8.0, 14.0])). While specificity for minor polyps (92.4 vs. 95.2) or no polyps (94.4 vs. 95.2) did not differ between fecal DNA and Hemoccult II, respectively; power to detect a difference was limited since the full sample was not tested. Other study limitations include poor precision in the estimates of test performance characteristics due to sample size issues, not including the other two nonadenocarcinomatous cancers in any calculations of relative test performance, excluding 20 percent of the study population for incomplete data, and questions about the generalizability of these findings to widespread population screening using fecal DNA. Generalizability concerns reflect the older age of study participants relative to the usual age of CRC screening (three-quarters over 65 years of age) and uncertainty about the accuracy of fecal DNA test performance in a community (as opposed to a specialized) laboratory setting. And, since this study was completed, the test version is no longer available on the commercial market and has been supplanted by other versions (1.1 and higher) for which there are not currently clinical cohort studies in screening populations.

One other fair-quality analysis from a population-based cohort study examined baseline stool samples for a single mutation of the K-ras gene in 441 older adults (aged 50–75 years) undergoing colonoscopy within two years. ^157^ These participants were similar to the overall study population, except that more reported a first-degree relative with CRC. The fecal test had zero percent sensitivity, testing positive in none of the 31 participants with advanced colorectal neoplasia, including seven patients with invasive CRC. The highest rate of mutant K-ras was reported in participants with a negative colonoscopy (7.5 percent). Limitations of this study include bias in the spectrum of patients self-selecting for colonoscopy, and the lag-time between stool collection and clinical diagnosis which could have affected test performance.

## Key Question 3a. What are age-specific rates of harm from colonoscopy and flexible sigmoidoscopy in the community practice setting?

### Colonoscopy

We found 16 fair- or good-quality studies evaluating clinically significant adverse events from colonoscopy conducted in predominantly asymptomatic persons (see Table 7). Three of these 16 studies were retrospective cohort studies, ^170^ – ^172^ while the other 13 studies were prospective. ^6,^ ^82,^ ^136,^ ^173^ – ^182^ Six of the prospective studies were conducted in trial settings and used colonoscopy as followup to FOBT, FS, or as a comparator for CTC. ^6,^ ^82,^ ^136,^ ^173,^ ^175,^ ^181^ Seven of these 15 studies were conducted primarily in community settings. ^170^ – ^172,^ ^174,^ ^177,^ ^180,^ ^181^ The 2002 review included only one of these studies. ^180^ In light of the stringency of our inclusion criteria, focusing on estimates of harms in the community practice setting, our studies were homogeneous enough to pool rates of complications. All studies were conducted in explicitly asymptomatic persons, or, at a minimum, in the case of 3 studies ^170,^ ^172,^ ^180^ in the community setting.

Table 7 Summary table key question 3a

Study Quality | Study Design Duration of followup | Procedure Information Operator characteristics | Patient characteristics (general, age, sex) | Adverse events
Colonoscopy Only
Kim 2007 ^182^ Fair | Prospective cohort | Colonoscopies: 3163 10 gastroenterologists | 98% Asymptomatic Age: 58.1 mean % female: 56% | Death: NR Perf: 7/3163 (0.2%) | | Bleed: NR Other Major: NR
Ko 2007 ^177,^ ^183^ Fair | Prospective cohort 30 days | Colonoscopies: 18271 89 gastroenterologists, with 10% trainee participation | Asymptomatic Age: 89% 50–79 years % female: 45 | Death: 0/18271 (0%) Perf: 4/18271 (0.02%) | | Bleed: 25/18271 (0.14%) Other major: 7/18271 (0.04%)
Levin 2006 ^171^ Fair | Retrospective cohort 30 days | Colonoscopies: 16318 96% gastroenterologists 2% internists | Asymptomatic Mean Age: 62 % female: 40 | Death: 1/16318 (0.006%) Perf: 15/16318 (0.09%) | | Bleed: 15/16318 (0.09%) Other major: 14/16318 (0.09%)
Cotterill 2005 ^174^ Fair | Prospective cohort NR | Colonoscopies: 324 2 family practitioners | Asymptomatic Age (range): 22–80 % female: 44 | Death: NR Perf: 0/324 (0%) | | Bleed: 0/324 (0%) Other major: NR
Rathgaber 2006 ^172^ Fair | Retrospective cohort 30 days | Colonoscopies: 12407 8 gastroenterologists | NR but community setting Mean age: 60 % female: 52 | Death: NR Perf: 2/12407 (0.016%) | | Bleed: 11/12407 (0.09%) Other major: 1/12407 (0.008%)
Newcomer 1999 ^180^ Fair | Prospective cohort 7 days | Total Colonoscopies: 270 (results for 250 reported) NR | NR but community setting Mean age: 52 % female: 43 | Death: 0/250 (0%) Perf: 0/250 (0%) | | Bleed: 0/250 (0%) Other major: NR
Korman 2003 ^170^ Fair | Retrospective cohort NR | Colonoscopies: 116000 264 gastroenterologists | NR but community setting Mean age: 69 % female: 73 | Death: NR Perf: 37/116000 (0.03%) | | Bleed: NR Other major: NR
Nelson 2002 ^179^ Good | Prospective cohort 30 days | Colonscopies: 3196 gastroenterologists at 13 sites | Asymptomatic Mean age: 63 % female: 3 | Death: 1/3196 (.03%) Perf: 0/3196 (0%) | | Bleed: 7/3196 (0.22%) Other major: 9/3196 (0.28%)
Ko 2006 ^176^ Fair | Prospective cohort 30 days | Colonoscopies: 502 8 gastroenterologists, with 36% trainee participation | Asymptomatic Age: 91% 50–79 years % female: 50.8 | Death: NR Perf: 0/502 (0%) | | Bleed: 4/502 (0.80%) Other major: 4/502 (0.80%)
Robinson 1999 ^181^ Fair | RCT for FOBT (colonoscopy if FOBT +) 30 days | Colonoscopies: 1474 NR | Asymptomatic Age range: 50–75 % female: 52 | Death: 0/1474 (0%) Perf: 5/1474 (0.3%) | | Bleed: 1/1474 (0.07%) Other major: 1/1474 (0.07%)
Lee 2006 ^178^ Fair | Prospective cohort 24 hours | Colnoscopies:1000 7 gastroenterologists | Asymptomatic Mean age: 51 % female: 43 | Death: NR Perf: NR | | Bleed: NR Other major: NR
Pickhardt 2003 ^136^ Fair | Prospective cohort for CTC (colonoscopy as reference) NR | Colonoscopies: 1239 14 gastroenterologists 2 colorectal surgeons | Asymptomatic Mean age: 58 % female: 41 | Death: NR Perf: NR | | Bleed: 1/1239 (0.08%) Other major: NR
FLEX SIG AND COLONOSCOPY
Segnan 2002 ^82^ Fair | RCT for flex sig (colonoscopy for f/u) NR | Flex Sig: 9911 Colonoscopies: 775 gastroenterologists in hospital endoscopy units | Average risk Age range: 55–64 % female: 50.0 | Flex sig | | Colonoscopy Death: NR Perf: 1/775 (0.13%) | Bleed: 1/775 (0.13%) Other major: NR
Death: NR Perf: 1/9911(0.01%) | Bleed: 0/9911(0%) Other major: 1/9911(0.01%)
Thiis-Evensen 1999 ^6^ Hoff 2001 ^188^ Fair | RCT for flex sig (colonoscopy for f/u) 14 days | Flex Sig: 446 Colonoscopies: 521 NR | Average risk Age range: 50–59 Mean age at f/u: 67 % female: 50, at f/u: 48 | Flex sig Death: 0/446 (0%) Perf: 0/446 (0%) | Bleed: 0/446 (0%) Other major: 1/446 (0.22%) | Colonoscopy Death: 0/521 (0%) Perf: 0/521 (0%) | Bleed: 0/521 (0%) Other major: 1/521 (0.19%)
Atkin 1998 ^173^ Fair | RCT for flex sig (colonoscopy for f/u) 1 day | Flex Sig: 1285 Colonoscopies: 76 NR | Average risk Age range: 55–64 % female: NR | Flex sig Death: 0/1285 (0%) Perf: NR | Bleed*: 40/1285 (3.1%) Other major: 3/1285 (0.23%) | Colonoscopy Death: NR Perf: NR | Bleed: NR Other major: NR
Kewenter 1996 ^175^ Fair | RCT for FOBT (endoscopy if FOBT or DCBE +) 12 days | Flex Sig: 2108 Colonoscopies: 190 NR | Asymptomatic Age range: 60–64 % female: NR | Flex sig Death: NR Perf: 3/2108 (0.14%) | Bleed: 0/2108 (0%) Other major: NR | Colonoscopy Death: NR Perf: 2/190 (1.05%) | Bleed: 1/190 (0.5%) Other major: NR
FLEX SIG ONLY
Viiala 2007 ^187^ Fair | Prospective cohort | Flex sig: 3402 Gastroenterologist, surgeons, supervised registrars, and GPs | Average risk Mean age: 60 % female: 41 | Death: NR Perf: 0/3402 (0%) | | Bleed: 0/3402 (0%) Other major: NR
Levin 2002 ^185^ Fair | Retrospective cohort 30 days | Flex Sig: 109534 Gastroenterologist, non-GI MD, or nurse. | Average risk Mean age: 61 % female:49 | Death*: 5/109534 (0.004%) Perf: 2/109534 (0.002%) | | Bleed: 2/109534 (0.002%) Other major: 3/109534 (0.003%)
Jain 2002 ^184^ Fair | Retrospective cohort NR | Flex Sig: 5017 Registered GI nurses | Average risk Age: >50 % female: NR | Death: 0/5017 (0%) Perf: 0/5017 (0%) | | Bleed: 0/5017 (0%) Other major: NR
Wallace 1999 ^186^ Fair | Prospective cohort NR | Flex Sig: 3701 Gastroenterologists, 1 NP, 2 PAs | Average risk Mean age: 59 % female: 51 | Death: 0/3701 (0%) Perf: 0/3701 (0%) | | Bleed: 0/3701 (0%) Other major: 0/3701 (0%)

We pooled the proportion of total serious complications from the 11 studies that reported all significant complications using a random-effects logistic model (n= 55,211). ^6,^ ^82,^ ^136,^ ^171,^ ^172,^ ^174^ – ^177,^ ^179,^ ^181,^ ^183^ Only three of these eleven studies reported the number or proportion of polypectomies performed, which ranged from 41 percent to 68 percent. ^171,^ ^172,^ ^179^ In these three studies, the majority (>85 percent) of serious complications, perforations, or major bleeding were in colonscopies with polypectomies. After pooling, we estimated that serious complications from colonoscopy in asymptomatic populations occurred in 3.1 per 1000 procedures (CI: 1.7, 5.8) (see Figure 2). We defined serious complications as adverse events requiring hospital admission, including perforation, major bleeding, diverticulitis, severe abdominal pain, cardiovascular events, and deaths attributable to colonoscopy. Based on pooling 13 studies (n= 173,391), ^6,^ ^82,^ ^136,^ ^170^ – ^172,^ ^174^ – ^177,^ ^179,^ ^181,^ ^182^ we found that perforations from colonoscopy in asymptomatic populations occurred in 5.6 per 10,000 procedures (CI: 2.2, 14.5). Based on pooling 12 studies (n= 55,461), we found that major bleeding from colonoscopy in asymptomatic populations occurred in 12 per 10,000 procedures (CI: 8.9, 16 per 10,000 procedures). ^6,^ ^82,^ ^136,^ ^171,^ ^172,^ ^174^ – ^177,^ ^179^ – ^181^ We were unable to obtain reliable pooled estimates for the proportion of other complications due to sparse data. We were also unable to obtain estimates for complications by age or age groups due to limitations in data reporting in the individual studies (see Discussion section).

Figure 2. Proportion of total serious complication in colonoscopy studies

While there was no significant statistical heterogeneity in combining studies to obtain pooled estimates, two studies appear to have slightly different estimates of harms. ^175,^ ^176^ In the first, Kewenter and colleagues used colonoscopies as followup exams for positive screening tests. Therefore, 113 of the 190 colonoscopies were conducted to remove proximal lesions seen on barium enema. In the second study by Ko and colleagues, both hospitalizations and emergency department visits were used to define major complications. These differences in study characteristics, along with relatively small study sizes, may account for the apparent, though not statistically significant, difference in harms estimates. We conducted a sensitivity analysis with and without the study by Ko and colleagues ^177^ because this study was only published as an abstract at the time of this report, though we were able to obtain additional information to assess quality from the authors. As shown on the respective forest plots, there was no meaningful difference in estimates when we excluded this study.

We also conducted exploratory meta-regressions to determine if study design, study setting by country, and population characteristics including age range and indication for endoscopy would affect estimates of harms for colonoscopy. None of these study-level characteristics appear to affect estimates of total serious complications in 11 studies (n= 55,211). However, the study setting by country is significantly associated with complications from perforations in 13 studies (n= 173,391) at p=0.04 level. Complications from perforations in the eight studies conducted in the US versus the five studies not conducted in the US were 2.5 to 28.0 per 10,000 procedures less common. Therefore, we conducted stratified analyses and report separately the estimates of harms from colonoscopy (Forest plots not shown). Total serious complications from colonoscopy in six studies conducted in the US were 2.9 per 1000 procedures (CI: 1.2, 7.6). Perforations from colonoscopy in eight studies conducted in the US occurred in 3.8 per 10,000 procedures (CI: 1.4 to 10.4 per 10,000 procedures). Major bleeding from colonoscopy in seven studies conducted in the US occurred in 12.3 per 10,000 procedures (CI: 7.8 to 19.3 per 10,000 procedures).

### Flexible Sigmoidoscopy

We found 8 fair- or good-quality studies that evaluated clinically significant adverse events from FS for colorectal cancer screening in a general-risk population (Table 7). ^6,^ ^82,^ ^173,^ ^175,^ ^184^ – ^187^ Two of these eight studies were retrospective cohort studies. ^184,^ ^185^ The remaining six studies were prospective. ^6,^ ^82,^ ^173,^ ^175,^ ^186^ – ^188^ Two of these prospective studies were conducted in randomized controlled trial settings evaluating FS. ^82,^ ^173^ One was conducted in a randomized controlled trial setting evaluating FOBT that used FS in their followup. ^175^ Only one of these studies was included in the prior 2002 review. ^173^ Similar to the colonoscopy studies, given the stringency of our inclusion criteria, focusing on estimates of harms in the community practice setting, our studies were homogeneous enough to pool rates of complications.

Using a random-effects logistic model, we pooled the proportion of total serious complications from the six studies that reported all significant complications from FS, not including those complications generated from followup colonoscopy (n= 126,985). ^6,^ ^82,^ ^173,^ ^175,^ ^184^ – ^186^ All of these studies, per their protocol, performed polypectomy with FS. Only two studies, however, reported the proportion of polypectomies performed, which was approximately 20 percent to 22 percent. ^173,^ ^175^ We found that serious complications from FS for colon cancer screening in average-risk populations are much lower than for colonoscopy screening, with a pooled point estimate of 3.4 per 10,000 procedures (CI: 0.6 to 19 per 10,000 procedures) (Figure 3). As with colonoscopy, we defined serious complications as adverse events requiring hospital admission, including perforation, major bleeding, severe abdominal complaints, myocardial infarction, syncope, and deaths attributable to FS. Based on seven studies (n= 134,119), ^6,^ ^82,^ ^175,^ ^184^ – ^187^ we found that perforations from FS in average-risk populations were relatively uncommon, with a pooled point estimate of 4.6 per 100,000 procedures (CI: 3.6 per million to 5.9 per 10,000 procedures) (forest plot not shown). We were unable to obtain reliable pooled estimates for the proportion of other complications due to sparse data. Again, we were also unable to obtain estimates for complications by age or age groups due to limitations in data reporting for the individual studies.

Figure 3. Proportion of total serious complication in flexible sigmoidoscopy studies

We conducted similar exploratory meta-regressions to determine if certain study-level characteristics would affect estimates of FS harms. Study setting by country appears to be significantly associated with total serious complications in six studies (n= 126,985) at p=0.02 level. The total serious complications in the two studies conducted in the US, versus the four studies not conducted in the US, were 3.1 to 13.0 per 10,000 procedures less common. We therefore conducted stratified analyses and report separately the estimates of harms from FS (Forest plots not shown). Total serious complications from FS after pooling the two studies conducted in the US had a point estimate of 0.9 per 10,000 procedures with very wide 95% confidence intervals (CI: 2.0 per million to 49.5 per 10,000 procedures). Perforations from FS in three studies conducted in the US were similarly imprecise with a point estimate of 0.2 per 10,000 procedures (CI: 0.9 per million to 3.5 per 10,000 procedures).

## Key Question 3b. What are the adverse effects of CT colonography (CTC) and/or fecal screening tests (high sensitivity fecal occult blood test (HS-FOBT), fecal immunochemical tests (FIT), and fecal DNA)?

### CT Colonography (CTC)

We found five fair-quality cohort studies that addressed potential adverse effects of screening CTC (see Table 8). ^136,^ ^189^ – ^191^ Adverse effects, including clinically important events requiring medical attention and evaluation of extra-colonic findings on CT, are addressed in the discussion section. Overall, it appears that the risk of perforation for screening CTC ranges from zero to less than 0.06 percent (6 per 10,000 CTC procedures). Evidence for clinically significant adverse effects primarily comes from two large retrospective studies (n= 33,793), which included both asymptomatic and symptomatic populations. ^190,^ ^191^ The overall risk for perforation ranged from 0.9 to 6 per 10,000 CTCs (2/21,923 to 7/11,870). Both studies, however, suggest that perforation rates are higher for symptomatic persons undergoing CTC. No perforations were reported in one study's screening subgroup of 11,707 procedures. ^190^ There was one perforation in the screening subgroup of 11,870 procedures (number of CTC screening procedures not reported). ^191^ Furthermore, it is unclear how clinically important CTC -associated perforations compare with asymptomatic perforations visualized on CT, or with noniatrogenic perforations. In the study by Sosna and colleagues, for example, six of the seven perforations were detected on CTC (number of symptomatic perforations not reported), and only four of the seven perforations required surgical intervention. ^191^ In the study by Pickhardt and colleagues, only one of the two perforations was clinically symptomatic and required treatment.

Table 8 Summary table key question 3b

Study Quality | Study Design Duration of followup | Procedure Information Operator characteristics | Patient characteristics | Adverse events
Kim ^137^ 2007 Fair | Prospective Cohort F/u NR | CTC: 3120 5 gastrointestinal radiologists | Age: 57.0 mean % female: 56 % symptomatic: 2 | Total Perforations: 0 Other major: 0
Pickhardt 2006 ^190^ Fair | Retrospective cohort Variable, generally 30 days | CTC: 21923 [underlined: Screening:] 11707 [underlined: Diagnostic:] 10216 radiologists at 16 centers; direct MD monitoring of CTC in 45.8% of cases | Age: NR % female: NR % symptomatic: 47 | Total Perforations: 2/21923 (0.009%) [underlined: Screening:] 0/11707 (0% [underlined: Diagnostic:] 2/10216 (0.02%) Other major: [underlined: exacerbated acute renal failure:] 2/21,923 (0.009%) [underlined: chest pain (not MI):] 1/21,923 (0.0045%)
Edwards 2004 ^189^ Fair | Prospective cohort NR | CTC: 340 2 radiologists | Age range: 50–54; 65–69 % female: 49 % symptomatic: 0 | Total Perforations: NR Other major: none
Sosna 2006 ^191^ Fair | Retrospective cohort NR | CTC: 11870 Staff and resident radiologists at 5 academic centers; non-radiologist MD at 6 non-academic centers | Mean age: 60 % female: 42 % symptomatic: NR | Total Perforations: 7/11870 (0.06%) [underlined: Screening:] 1, unknown denominator [underlined: Diagnostic:] 6, unknown denominator Other major: NR
Pickhardt 2003 ^136^ Fair | Prospective Cohort NR | CTC: 1247 6 radiologists | Mean age: 58 % female: 41 % symptomatic: 0 | Total Perforations: NR Other major: none

The three prospective cohort studies (n= 4707), which were conducted in predominantly asymptomatic, average-risk screening populations, did not find any evidence of clinically significant adverse events from CTC. ^136,^ ^182,^ ^189^ One study reported three syncopal events related to a magnesium citrate/sodium picosupphate (SPS) bowel preparation, a procedure that has subsequently been discontinued. ^189^ We found two reviews providing estimates of ionizing radiation exposure per CTC exam. ^192,^ ^193^ Estimates of total radiation exposure per exam range from 1.6 to 24.4mSv for dual positioning (both supine and prone positions) with a median dose estimate of 8.8mSv or 10.2mSv. ^192,^ ^193^ These estimates are consistent with those provided in other primary articles and multiple background/reference articles. ^117,^ ^118,^ ^120,^ ^194^ – ^201^ We identified no studies that directly measured the risk for stochastic effects (e.g., cancer) caused by radiation exposure from CTC. We discuss the indirect evidence for the potential adverse effects of low-dose ionizing radiation in the discussion section.

Fecal screening tests. We found no studies meeting our inclusion criteria that addressed adverse effects of fecal screening tests, including HS-FOBT, FITs, or fecal DNA tests.