# Introduction

## Scope and Purpose

We conducted this systematic review to support the USPSTF in updating its 2002 recommendation on screening for colorectal cancer (CRC). ^1^ The previous systematic review, on which this recommendation was based, ^1,^ ^2^ found direct evidence supporting the effectiveness of home fecal occult blood testing (FOBT) for decreasing disease-specific mortality. Three high-quality randomized controlled trials (RCT) of FOBT showed CRC-mortality reductions of 15 percent to 33 percent over 8 to 13 years. ^3^ – ^5^ The review reported a reduction in CRC incidence with flexible sigmoidoscopy (FS) screening (RR 0.20, CI: 0.03, 0.95) and a nonsignificant, but possible, reduction in CRC mortality based on the results of a small RCT of FS. ^6^

The review also found evidence that sigmoidoscopy, and possibly colonoscopy, are associated with decreased mortality from CRC within reach of the endoscope. One high-quality, case-control study of rigid sigmoidoscopy found nine percent of those dying from CRC within 20 cm of the anus had had a previous sigmoidoscopy, while 24 percent of persons with CRC within 20 cm of the anus who did not die of this cancer had received the test. ^7^ The reduction in distal CRC mortality (adjusted OR 0.41,CI: 0.25, 0.69 was not seen in those dying of more proximal colonic cancers (adjusted OR 0.96), suggesting that screening reduced risk for death from CRC located in the sections of the colon reached by the sigmoidoscope. Evidence to support FOBT combined with sigmoidoscopy came from a nonrandomized trial suggesting a 43 percent reduction in CRC-mortality after nine years from combined testing compared with rigid sigmoidoscopy alone, although differences were not statistically significant. ^8^ One case-control study showed lower odds of having had a previous colonoscopy in those dying from CRC (OR 0.43, CI: 0.30, 0.73), compared to controls without CRC. ^9^ The previous review also cited support for colonoscopy screening from the National Polyp Study (NPS), which shows a 76 to 90 percent reduction of CRC incidence (compared to historical controls). ^10^ The effectiveness of barium enemas and virtual colonoscopy using CT colonography (CTC) in reducing CRC death or incidence was unknown.

During 2006, while planning the updated evidence review on colorectal cancer screening, AHRQ decided to devote some funding to a decision analysis on CRC screening to be conducted in parallel with this systematic review. The Task Force members who were designated to the colorectal cancer screening topic saw this as an opportunity to bring useful information to the Task Force's deliberations that a systematic review would not likely address, such as the optimal age to begin or end screening and considerations of repeated screening over time (screening programs).

The Task Force determined the scope for both the systematic evidence review and the decision analysis, with an eye toward these two reports providing complementary information about the important clinical questions that could inform effective use of screening in practice. The systematic review focused on the accuracy and potential harms of newer CRC screening technologies and, to a lesser extent, on updating test accuracy and harms data on already-recommended screening tests. The decision analysis focused on projected benefits to a cohort beginning CRC screening at age 40 years or later for different screening strategies, different beginning and ending ages, and different intervals for re-screening after a normal test, with varying screening test adherence. ^11^ These two reports were used together by the USPSTF to make its updated recommendation on CRC screening.

As an update, this report extends the time period of the previous report to update information on several currently recommended CRC screening tests (e.g., FOBT, FS, and colonoscopy); the update is limited to important supplemental data on screening test performance, benefits, and harms. The scope of this report was expanded to include the evidence for screening test performance, benefits, and harms of newer CRC screening tests not previously recommended by the USPSTF (e.g., high-sensitivity guaiac fecal occult blood tests (HS-FOBT), fecal immunochemical fecal tests (FITs), fecal DNA tests, and CTC). The USPSTF chose not to update the evidence on DCBE as a CRC screening test (see Methods section for rationale). This report does not address the effectiveness of screening programs based on these tests, as the concurrent decision analysis addresses this topic.

## Background

### Condition Definition

Colorectal cancer or colorectal adenocarcinoma (CRC) is a malignant tumor arising within the walls of the large intestine, including the segments in the cecum, ascending colon, transverse colon, descending colon, sigmoid, and rectum. CRC does not include tumors in the tissues of the anus or the small intestine. Adenomas are benign epithelial tumors that are considered precancerous lesions. Adenomas can have different degrees of dysplasia or different histologic characteristics (tubular, tubulovillous, and villous) associated with increasing malignant potential. Carcinoma in situ refers to adenomas with severe dysplasia, while lesions that invade the muscularis mucosa are considered adenocarcinomas. Advanced neoplasia refers to a composite outcome including adenocarcinoma, adenomas with high grade dysplasia or villous histology, and adenomas 10 mm or greater in diameter.

### Burden of Preventable Illness

CRC continues to cause significant morbidity and mortality in the United States. Among all cancers, CRC ranks third in incidence and second in cause of cancer death for both men and women. ^12^ While overall CRC-related death rates in both men and women have recently declined, the increasing proportion of individuals over the age of 65 in the US is expected to increase the absolute number of CRC deaths. ^13^ Statistics from the National Cancer Institute (NCI) indicate that the annual incidence of CRC in the US is 52.0 cases per 100,000 persons, ^14^ with more than 90 percent of diagnoses occurring in individuals over the age of 50 years. ^15^ The lifetime risk of CRC is approximately 5.9 percent for men and 5.4 percent women, with a lifetime mortality rate of 2.4 percent and 3.3 percent respectively. ^16^

Screening for CRC can impact both primary prevention (finding precancerous polyps that could later become malignant) and secondary prevention (detecting early cancers that can be more effectively treated). While there is general consensus that CRC screening reduces disease-specific mortality, newer screening tests have created uncertainty about the optimal methods for CRC screening in the general population.

Burden of disease by socio-demographic factors. Increasing age, male sex, and Black race are associated with an increased incidence of new CRC cases (see Table 1). Age-adjusted incidence rates for CRC are higher in men than women: 60.8 versus 44.6 per 100,000 persons (see Table 2). Blacks have the highest incidence of CRC among the racial/ethnic subgroups, 72.6 and 55.0 per 100,000 persons, respectively (See Table 1). Blacks also have a disproportionately high disease-specific mortality. ^17^ – ^21^ Over the past 20 years, CRC mortality rates have decreased more among Whites than Blacks. ^22^ While the overall annual CRC-related death rate is 19.2 deaths per 100,000 persons, the rate for Blacks is 26.4 per 100,000 persons, which is nearly double the mortality for Hispanics, Asian/PI, and AI/AN individuals. ^15^

Table 1 Crude rates of colorectal cancer by age, sex, race/ethnicity, SEER 2000-2004

| All Races | Black | NH White | Asian/PI | Hispanic | AI/AN
Males
40–44 | 14.7 | 19.7 | 14.6 | 13.6 | 11.4 | 7.4
45–49 | 29.7 | 37.0 | 29.2 | 28.2 | 22.5 | 21.6
50–54 | 59.7 | 79.9 | 58.8 | 49.7 | 45.5 | 47.9
55–59 | 93.6 | 129.2 | 91.2 | 82.2 | 75.1 | 68.4
60–64 | 147.8 | 197.9 | 147.6 | 105.7 | 117.5 | 155.0
65–69 | 223.9 | 261.9 | 224.2 | 188.7 | 185.7 | 154.6
70–74 | 300.6 | 338.9 | 303.7 | 236.4 | 253.7 | 227.4
75–79 | 379.0 | 436.5 | 383.1 | 321.5 | 303.0 | 204.6
80–84 | 428.9 | 503.0 | 438.3 | 339.0 | 311.0 | 312.1
85+ | 460.5 | 497.0 | 473.4 | 350.9 | 313.7 | 171.5
Females
40–44 | 13.6 | 17.1 | 13.0 | 13.5 | 11.1 | 14.8
45–49 | 25.3 | 33.6 | 24.2 | 24.4 | 19.0 | 28.8
50–54 | 45.6 | 67.5 | 42.7 | 41.1 | 36.1 | 42.3
55–59 | 65.2 | 96.8 | 62.4 | 58.0 | 48.3 | 59.0
60–64 | 98.1 | 144.4 | 94.7 | 72.5 | 78.2 | 103.4
65–69 | 152.4 | 196.1 | 153.3 | 120.3 | 110.4 | 129.0
70–74 | 201.7 | 242.0 | 205.2 | 151.5 | 145.7 | 204.0
75–79 | 272.5 | 313.0 | 282.0 | 196.6 | 191.7 | 247.6
80–84 | 334.5 | 377.8 | 343.8 | 255.4 | 235.5 | 270.4
85+ | 377.4 | 388.0 | 386.8 | 288.5 | 278.3 | 209.3

Data from SEER CanQues: http://seer.cancer.gov/canques/incidence.html

NH = nonHispanic; PI = Pacific Islander; AI = American Indian; AN = Alaska Native

Incidence noted per 100,000; all values adjusted to US 2000 standard population

Table 2 Age-adjusted incidence of colorectal cancer by site, sex, and race/ethnicity, SEER 2000-2004

| All Races | Black | NH White | Asian/PI | Hispanic | AI/AN
Males
All sites | 60.8 | 72.6 | 61.2 | 49.7 | 47.5 | 42.1
Total distal | 31.5 | 32.1 | 31.5 | 30.5 | 26.5 | 25.9
Total proximal | 17.5 | 24.2 | 17.7 | 13.3 | 12.5 | 9.3
Ratio proximal: all | 0.288 | 0.333 | 0.289 | 0.268 | 0.263 | 0.221
Females
All sites | 44.6 | 55 | 44.7 | 35.3 | 32.9 | 39.6
Total distal | 20 | 22.1 | 19.8 | 19.2 | 17.3 | 20.2
Total proximal | 14.8 | 18.6 | 14.1 | 10.4 | 9.4 | 9.6
Ratio proximal:all | 0.332 | 0.338 | 0.315 | 0.295 | 0.286 | 0.242

Data from SEER CanQues: http://seer.cancer.gov/canques/incidence.html

NH = non-Hispanic; PI = Pacific Islander; AI = American Indian; AN = Alaska Native

Incidence noted per 100,000; all values adjusted to US 2000 standard population

Distal colon includes rectum and sigmoid; proximal colon includes all sites proximal to sigmoid

Anatomic location of CRC by socio-demographic factors. Age, sex, and race/ethnicity also appear to influence the anatomic distribution of CRC (see Table 2). Data from the NCI's Surveillance, Epidemiology, and End Results Program (SEER) demonstrate a proximal migration of CRC over the past two decades, which is attributed to a decrease in incidence of distal CRCs, and an aging population in which proximal lesions are more common. ^23^ This proximal migration appears in both men and women, and in Whites and Blacks. ^23^ SEER data from 2000 to 2004 suggest that the current age-adjusted ratio for proximal CRC incidence is highest among Blacks for both men and women (Table 2). ^24^ This difference between Whites and Blacks was not evident during the 1970s. ^22^

### Risk Factors

Most cases of CRC are sporadic, with 75 percent of cases developing in average-risk persons, versus about 20 percent of cases developing in persons with some type of family history. The remainder of cases develop in persons who have predisposing inflammatory bowel disease or a known genetic mutation, including familial adenomatous polyposis (FAP), hereditary nonpolyposis colorectal cancer (HNPCC), and I1307K, which is prevalent in Ashkenazi Jews. ^24^ – ^27^

Case-control and cohort studies indicate an approximately two-fold increase in CRC risk for persons with a first-degree relative (e.g., parent, sibling, or child) with CRC. This increased risk is also applicable to first-degree relatives of individuals with colorectal adenomas. ^26,^ ^28^ – ^37^ CRC may be associated with nongenetic risk factors, such as smoking or obesity, although evidence is limited to case-control and cross-sectional data. ^38^ There has been substantial progress in understanding the molecular genetics of colorectal cancer, and these scientific advances underpin the efforts to develop DNA testing (fecal or plasma) for CRC detection.

### Natural History

Impact of polypectomy on natural history and CRC incidence. It is estimated that at least 95 percent of colorectal cancers arise from preexisting polypoid or flat adenomas. ^39,^ ^40^ The notion of an adenoma-carcinoma sequence stems from observations of a greatly elevated CRC risk status for patients with hereditary polyposis syndromes ^41,^ ^42^ and from observational studies showing an estimated 60 to 90 percent reduction in CRC incidence after polypectomy during colonoscopy or FS. ^6,^ ^7,^ ^10,^ ^43^ – ^46^

The most commonly cited study, the National Polyp Study (NPS), reported a 76 to 90 percent reduction in observed CRC incidence over about 6 years in a surveillance cohort following colonoscopy and polypectomy for newly detected adenomas, compared with expected rates derived from three historical control cohorts. ^10^ In a similar Italian study, the observed CRC incidence over 10 years was reduced by about 66 percent in a surveillance cohort of persons with newly detected adenomas (5mm or larger) who underwent colonoscopy and polypectomy, compared with expected rates derived from a statistically modeled reference cohort. ^44^ While these estimates are widely cited, they should be interpreted with caution as both studies relied on historical controls for comparison, which can be unreliable. In addition, these estimates may have limited generalizability, given the extremely low incidence of CRC in these two observational studies. Large dietary-intervention and chemoprevention trials to prevent CRC report post-polypectomy CRC incidence rates three to four times higher than those seen in the two aforementioned observational studies. ^47^ – ^51^ While the difference in CRC incidence rates between these studies are likely multi-factorial (i.e., due to both population and study design characteristics), this issue is beyond the scope of our review, but is explored elsewhere. ^40,^ ^52^

Additional evidence for the reduction in CRC incidence or mortality comes from FS studies. The most convincing evidence from sigmoidoscopy studies comes from well done case-control studies that have demonstrated a decrease in CRC mortality, and in some cases, in CRC incidence. The landmark case-control study by Selby and colleagues found a 60 percent reduction in mortality from distal CRC over 10 years in persons who received rigid sigmoidoscopes with polypectomy, compared to matched contemporaneous controls (adjusted for previous CRC, family history of CRC, and number of periodic health checkups). ^7^ These results have been reproduced in subsequent well done case-control studies, ^9,^ ^45^ one of which showed a probable reduction in CRC incidence. ^46^ In the Telemark Polyp Study, the observed CRC incidence was reduced by about 80 percent after 13 years in a screening cohort of 400 adults undergoing FS, followed by colonoscopy and polypectomy, and by surveillance, compared with a concurrent control cohort of 399 adults receiving no CRC screening (10 cancers in the control group compared with 2 in the screening group). ^6^ However, no clear CRC mortality benefit was seen (1 CRC death vs. 3 deaths in the controls) and there was a higher overall mortality rate reported in the screening group (RR 1.57, CI: 1.03, 2.4), which is difficult to interpret.

Despite the uncertainty around magnitude of benefit, these studies give us the best available estimates of polypectomy's impact on CRC incidence. We cannot definitively articulate the degree of CRC incidence reduction, however, due to CRC screening and resulting polypectomies without randomized controlled trials.

Significance of polyp size. While there is general agreement that the risk of in-dwelling cancer, or progression to cancer, for polyps 10 mm or larger is sufficient to require immediate removal, the necessity and benefit of removing small polyps is not clear. ^53,^ ^54^ Sensitivity estimates for optical methods (e.g., CTC, FS, and colonoscopy) depend on the threshold for the size of polyp considered clinically meaningful. The threshold for polyp size also determines the number of colonscopy referrals that will result from primary CTC and other visualization-only screening methods.

No large observational studies are available to determine the consequences of untreated adenomas. One small observational study (n=226) of patients with unresected polyps greater than 10 mm found that 37 percent of polyps enlarged over a mean followup time of 68 months. The cumulative risk of malignancy at the polyp site at 5, 10, and 20 years was 2.5 percent, 8 percent, and 24 percent respectively. ^55^ The natural history of smaller adenomas, particularly those of different sizes (e.g., 5 mm or under, 6 to 9 mm), is unknown. Pilot-sized studies of all small (<10 mm) adenomatous polyps observed in situ by serial endoscopy suggest that many remain dormant or regress during a 2–3 year period. The tendency towards net growth or regression, however, may vary by polyp size and histology, as well as by other characteristics such as patient age, tumor location, and number of lesions. ^56,^ ^57^

Cross-sectional studies using colonoscopy registries report CRC prevalence in polyps of various sizes. The overall CRC prevalence in any-sized lesion found in screening colonoscopy studies in the US is approximately 0.4 percent. ^58^ – ^69^ A study from the Clinical Outcomes Research Initiative (CORI) database of 1,137 average-risk patients, whose largest polyp was 6–9 mm on screening colonoscopy, found invasive cancer in only two patients at the time of colonoscopy (0.2 percent). ^70^ Other colonoscopy database studies (that include high-risk populations) indicate that the prevalence of CRC in lesions less than 6 mm in diameter ranges from zero to 0.8 percent. The prevalence in lesions 6–9 mm ranges from 0.4 percent to 1.1 percent. ^71^ – ^75^ While advanced neoplasia (see below) is somewhat more common than CRC in small polyps, the clinical significance of advanced neoplasia is unknown.

Advanced neoplasia. Current efforts to characterize the accuracy of optical screening methods have evaluated the sensitivity of different tests not only for CRC, but also for advanced neoplasia. Advanced neoplasia is a composite endpoint defined as an adenoma 10 mm or greater in size, or a smaller adenoma with at least 25 percent villous histology, or those containing high-grade dysplasia or invasive carcinoma. It is therefore important to understand both the impact of polypectomy of advanced neoplasias on risk of future CRC, and conversely the impact of leaving an advanced neoplastic lesion intact on risk of future CRC. In a followup of 1618 patients with rectosigmoid adenomas removed during sigmoidoscopy and polypectomy, the risk of subsequent CRC was increased at least three-fold in those with tubulovillous, villous, or large (≥ 10 mm) adenomas, compared with those with other types of rectosigmoid adenomas. ^76^ The perceived increase in malignant potential of advanced neoplastic lesions is also derived from examining the prevalence of adenocarcinoma polyps removed during colonoscopies or from consecutive surgical specimens at a single institution. In these cross-sectional studies, the approximate prevalence of invasive carcinoma among polyps varied by histology. Invasive carcinomas in polyps with surface villous histology ranged from 10 to 40 percent, from 6 to 23 percent among polyps with surface tubulovillous histology, from 2 to 5 percent among polyps with surface tubular histology, ^77^ – ^80^ and were 34.1 percent among polyps with surface advanced dysplasia. ^77^

There have been no prospective studies describing the natural history of advanced neoplasia, and no longitudinal studies have validated the clinical benefit of targeting advanced neoplasia in screening populations. The results of three FS trials using advanced neoplasia criteria as a threshold for colonoscopy referral are pending. ^81^ – ^83^

Flat and depressed adenomas. The prevalence of flat and depressed (nonpolypoid) adenomas in screening populations is largely unknown. However, one recent study in US veterans suggests that nonpolypoid colorectal neoplasms are relatively common, present in about 6 percent of the screening group and in about 15 percent of the asymptomatic surveillance group. ^84^ The advent of dye-spraying and magnified examination of the colon using chromoendoscopy allows better detection of flat and depressed lesions than standard colonoscopy. ^84^ – ^87^ In British studies of high-risk populations, flat and depressed lesions were more likely to contain advanced dysplasia or invasive cancer than polypoid lesions, ^88,^ ^89^ with a doubling of the odds of carcinoma in flat or depressed lesions compared with polypoid lesions in US veterans undergoing screening (OR 2.01, CI: 0.27, 15.3). ^84^ In contrast, investigators in the National Polyp study found no increase in risk for high-grade dysplasia initially, or at surveillance, within flat adenomas when compared to polypoid adenomas. ^90^ – ^92^ The Japan Polyp Study is currently examining the incidence of CRC during a followup surveillance exam at 2 versus 4 years after patients have had two serial chromoendoscopy clearing examinations. ^93^

### Colorectal Cancer Screening

Rationale and current practice. Colorectal cancer meets the criteria for a screening condition—it is prevalent and has a known preclinical period during which the majority of CRC develops from precursor lesions, such as adenomatous or other histologically advanced polyps. Based on evidence from randomized controlled trials (RCT), a screening program using simple, reasonably acceptable, guaiac fecal occult blood screening tests reduces CRC mortality when used with repeated application over time and endoscopic followup of positive results. ^94^ Other screening approaches are recommended based on extrapolation from the RCT evidence of screening program effectiveness, on specific test accuracy, and on other studies supporting an expected benefit from these tests when applied in a program of screening. No current CRC screening tests, however, are without drawbacks, including potential harms, limited accessibility, or imperfect acceptability to patients. Ongoing research aims to make more accurate screening tests available to further improve CRC screening programs.

Despite multiple professional organizations recommending CRC screening for all individuals 50 years of age or older, ^95^ – ^98^ serial national surveys document relatively low rates of CRC screening in the US, although these rates do appear to be increasing over time. ^99^ – ^104^ Between 2002 and 2004, the number of states (including District of Columbia) where 60 percent or more of the population aged 50 years or older had been screened for CRC increased from eight states in 2002 to 15 in 2004. ^105^ In the 2006 Behavioral Risk Factor Surveillance survey 60.8 percent of adults 50 years or older reported recent colorectal screening using either endoscopy in the preceeding 10 years, or FOBT within the past year. ^104^ There is also increasing evidence of race/ethnic and sex disparities in CRC screening, with lower rates of CRC screening in Nonwhite and Hispanic populations, ^103,^ ^106,^ ^107^ fewer colonoscopies in women, ^103,^ ^106^ and lower screening rates in areas with higher poverty rates. ^108^

CRC screening tests commonly used in primary care include home FOBT, FS, and colonoscopy. ^100,^ ^103,^ ^109^ Colonoscopy utilization for CRC screening has increased recently, and use of FS has decreased, ^110^ due largely to the Center for Medicare and Medicaid Service's 2001 decision to cover screening colonoscopy for patients on Medicare, and similar decisions by private pay insurers. Public perceptions of accuracy also play an important role in this issue. ^103^ Significant variation in community CRC screening practices, which may impact effectiveness of screening, has also been reported. Some primary care providers rely on in-office FOBT, for example, which has different test characteristics than home FOBT, the test which has been shown to be efficacious. ^111^ There also appears to be variation in practice for followup of positive FOBT (e.g., using FS instead of colonoscopy). ^112^ Lastly, there remains significant variation in operator characteristics for endoscopies, both FS and colonoscopy, which may affect test characteristics for screening and confirmatory endoscopy. ^52^

While issues of test acceptability to patients and available capacity are important concepts for considering screening tests, exploring these issues was beyond the scope of this report. Similarly, recommended methods of surveillance in those who have screened positive was beyond the scope of this report, but has been reviewed by others. ^96,^ ^113^

### Previous USPSTF Recommendation

In 2002, the USPSTF issued the following recommendations about screening for colorectal cancer:

- The USPSTF strongly recommends that clinicians screen men and women 50 years of age or older for colorectal cancer. (A Recommendation)
- Rationale: The USPSTF found fair-to-good evidence that several screening methods are effective in reducing mortality from colorectal cancer. The USPSTF concluded that the benefits from screening substantially outweigh potential harms, but the quality of evidence, magnitude of benefit, and potential harms vary with each method.
- The USPSTF found good evidence that periodic fecal occult blood testing (FOBT) reduces mortality from colorectal cancer and fair evidence that sigmoidoscopy alone or in combination with FOBT reduces mortality. The USPSTF did not find direct evidence that screening colonoscopy is effective in reducing colorectal cancer mortality; efficacy of colonoscopy is supported by its integral role in trials of FOBT, extrapolation from sigmoidoscopy studies, limited case-control evidence, and the ability of colonoscopy to inspect the proximal colon. Double-contrast barium enema offers an alternative means of whole-bowel examination, but it is less sensitive than colonoscopy, and there is no direct evidence that it is effective in reducing mortality rates. The USPSTF found insufficient evidence that newer screening technologies (for example, computed tomographic colonography) are effective in improving health outcomes.